# SEARCH STRATEGIES

## BARIATRIC SURGERY – MALADAPTIVE EATING (From Livhits and colleagues)

### SEARCH METHODOLOGY

#### SEARCH #1

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed -10/1/2009-12/6/2013

LANGUAGE:

English

SEARCH STRATEGY:

[bariatric OR obesity/su OR (obesity AND (surgery OR surgical OR operation OR pre-operation)) OR (obese OR (weight AND reduce) OR (weight AND reducing) OR (weight AND reduction) OR weight-reducing OR (decreas* AND weight) OR “weight loss” OR (weight AND lost) OR overweight) AND (surgery OR surgical OR operation OR pre-operation)) OR gastric band* OR gastric bypass OR stomach bypass OR (laparoscop* AND band) OR (laparoscop* AND bands) OR (laparoscop* AND banding) OR lapband* OR “lap band” OR “lap bands” OR “lap banding” OR gastrectom* sleeve* OR sleeve gastrectom* OR biliopancreatic bypass OR duodenal switch* OR duodenum switch* OR biliopancreatic diver* OR gastroplasty OR gastric restrict*

AND

“adaptation, psychological” OR psychology OR psychological OR psychiatry OR psychiatric OR mental illness OR mentally ill OR binge eating” OR bulimia OR bulimic OR eating disorder* OR feeding behavio* OR eating behavio* OR maladaptive eating OR “portion size” OR “sweet eater” OR “volume eater”

NUMBER OF RESULTS: 1127

TOTAL AFTER FILTERING IN ENDNOTE TO REMOVE ANIMAL-ONLY STUDIES AND NON-RELEVANT MATERIAL (ARTICLES NOT RELATING TO BARIATRIC SURGERY OR OBESITY): 462

Search updated on 8/13/2014, number of results: 230

#### SEARCH #2:

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed -10/1/2009-12/6/2013

LANGUAGE:

English

SEARCH STRATEGY:

[bariatric OR obesity/su OR (obesity AND (surgery OR surgical OR operation OR pre-operation))

OR

gastric band* OR gastric bypass OR stomach bypass OR (laparoscop* AND band) OR (laparoscop* AND bands) OR (laparoscop* AND banding) OR lapband* OR “lap band” OR “lap bands” OR “lap banding” OR gastrectom* sleeve* OR sleeve gastrectom* OR biliopancreatic bypass OR duodenal switch* OR duodenum switch* OR biliopancreatic diver* OR gastroplasty OR gastric restrict*]

AND

“adaptation, psychological” OR psychology OR psychological OR psychiatry OR psychiatric OR mental illness OR mentally ill OR binge eating” OR bulimia OR bulimic OR eating disorder* OR feeding behavio* OR eating behavio* OR maladaptive eating OR “portion size” OR “sweet eater” OR “volume eater”

AND

predict* or pre-surgical or pre-surgery or presurgery or presurgical or candidate*

NUMBER OF RESULTS: 217

TOTAL AFTER FILTERING IN ENDNOTE TO REMOVE ANIMAL-ONLY STUDIES: 172

Search updated on 8/13/2014, number of results: 53

#### SEARCH #3

DATABASE SEARCHED & TIME PERIOD COVERED:

MEDLINE ON OVID -1/1/2009-2014

LANGUAGE:

English

SEARCH STRATEGY:

obese or obesity or (weight adj3 reduce) or (weight adj3 reducing) or (weight adj3 reduction) or weight-reducing or (decreas* adj3 weight) or “weight loss” or (weight adj3 lost) or overweight) IN ALL FIELDS

AND

surgery or surgical or operation or pre-operation or pre-operative or presurgery or presurgical or pre-surgery or pre-surgical (((obese or obesity) adj3 surgery) or surgical)IN ALL FIELDS

OR

gastric band* or “gastric bypass” or “stomach bypass” or laparoscop*) adj3 band) or laparoscop*) adj3 bands) or laparoscop*) adj3 banding) or lapband* or “lap band” or “lap bands” or “lap banding”) OR

(gastrectom* adj3 sleeve*) or (sleeve adj3 gastrectom*) or (biliopancreatic adj3 bypass) or (duodenal adj3 switch*) or (duodenum adj3 switch*) or (biliopancreatic adj3 diver*) or gastroplasty or (gastric adj3 restrict*) OR bariatric OR ((obese or obesity) adj3 surgery or surgical) IN ALL FIELDS

AND

“adaptation, psychological” or psychology or psychological or psychiatry or psychiatric or mental illness or mentally ill OR (binge adj3 eating) or bulimia or bulimic or (eating adj3 disorder*) or (feeding adj behavio*) or (eating adj3 behavio*) or (maladaptive adj3 eating) or “portion size” or “sweet eater” or “volume eater” IN ALL FIELDS

AND

(predict* or pre-surgical or pre-surgery or presurgery or presurgical or candidate*).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]

NUMBER OF RESULTS: 1030

NUMBER AFTER INTERNAL DUPLICATE REMOVAL: 911

TOTAL AFTER REMOVAL OF DUPLICATES WITH PUBMED SEARCHES, ALONG WITH ANIMAL-ONLY STUDIES AND NON-RELEVANT MATERIAL: 40

Search updated on 8/14/2014, number of results: 92

#### SEARCH #4

DATABASE SEARCHED & TIME PERIOD COVERED:

PsycINFO - 10/1/2009-12/10/2013

LANGUAGE:

English

SEARCH STRATEGY:

bariatric OR obese OR obesity OR (weight AND reduce) OR (weight AND reducing) OR (weight AND reduction) OR weight-reducing OR (decreas* AND weight) OR “weight loss” OR

(weight AND lost) OR overweight ) AND ( surgery OR surgical OR operation OR pre-operation OR pre-surgical or pre-surgery or presurgery or presurgical ) ) OR (gastric band* OR gastric bypass OR stomach bypass OR (laparoscop* AND band) OR (laparoscop* AND bands) OR (laparoscop* AND banding) OR lapband* OR “lap band” OR “lap bands” OR “lap banding” OR gastrectom* sleeve* OR sleeve gastrectom* OR biliopancreatic bypass OR duodenal switch* OR duodenum switch* OR biliopancreatic diver* OR gastroplasty OR gastric restrict*

AND

predict* OR candidate*

NUMBER OF RESULTS: 178

NUMBER AFTER REMOVAL OF DUPLICATES, ANIMAL-ONLY STUDIES AND NON-RELEVANT MATERIAL: 78

Search updated on 8/14/2014, number of results: 21

## BARIATRIC SURGERY – PSYCHIATRIC DISORDERS (From Livhits and colleagues)

### SEARCH METHODOLOGY

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 10/1/2009-12/11/2013

LANGUAGE:

English

SEARCH STRATEGY:

gastric band* OR gastric bypass OR stomach bypass OR (laparoscop* AND band) OR (laparoscop* AND bands) OR (laparoscop* AND banding) OR lapband* OR “lap band” OR “lap bands” OR “lap banding” OR gastrectom* sleeve* OR sleeve gastrectom* OR biliopancreatic bypass OR duodenal switch* OR duodenum switch* OR biliopancreatic diver* OR gastroplasty OR gastric restrict*

OR

bariatric OR obesity/su OR (obesity[ti] AND (surgery OR surgical OR operation OR pre-operation OR pre-operative OR pre-surgical or pre-surgery or presurgery or presurgical))

OR

(obese[ti] OR (weight AND reduce) OR (weight AND reducing) OR (weight AND reduction) OR weight-reducing OR (decreas* AND weight) OR “weight loss” OR (weight AND lost) OR overweight) AND (surgery OR surgical OR operation OR pre-operation)

AND

“Adjustment Disorders” [Mesh] OR adjustment[tiab] OR “Affective Disorders, Psychotic” [Mesh] OR affective disorder*[tiab] OR psychotic[tiab] OR psychosis[tiab] OR “Bipolar Disorder” [Mesh] OR bipolar[tiab] OR counsel*[tiab] OR “Depression” [Mesh] OR depression[tiab] OR depressive[tiab] OR “Depression, Chemical” [Mesh] OR “Depressive Disorder” [Mesh] OR “Depressive Disorder, Major” [Mesh] OR “Dysthymic Disorder” [Mesh] OR dysthymic OR “Psychiatric Counseling” OR “Psychiatric evaluation” OR “Seasonal Affective Disorder” [Mesh] OR “seasonal affective disorder” OR psychopatholog*

NUMBER OF RESULTS: 680

NUMBER AFTER REMOVAL OF DUPLICATES WITH MALADAPTIVE EATING SEARCHES: 473

NUMBER AFTER MANUAL FILTERING IN ENDNOTE TO REMOVE ANIMAL-ONLY STUDIES & NON-RELEVANT MATERIAL: 108

Search updated 8/15/2014, number of results: 174

## TARGETED PSYCHOLOGICAL LITERATURE DATABASE SEARCH

### SEARCH METHODOLOGY

DATABASE SEARCHED & TIME PERIOD COVERED:

PsycINFO – 1/1/2009-12/12/2013

LANGUAGE:

English

SEARCH STRATEGY:

gastric band* OR gastric bypass OR stomach bypass OR (laparoscop* AND band) OR (laparoscop* AND bands) OR (laparoscop* AND banding) OR lapband* OR “lap band” OR “lap bands” OR “lap banding” OR gastrectom* sleeve* OR sleeve gastrectom* OR biliopancreatic bypass OR duodenal switch* OR duodenum switch* OR biliopancreatic diver* OR gastroplasty OR gastric restrict*

OR

(bariatric OR obese OR obesity OR (weight AND reduce) OR (weight AND reducing) OR (weight AND reduction) OR weight-reducing OR (decreas* AND weight) OR “weight loss” OR (weight AND lost) OR overweight ) AND (surgery OR surgical OR operation OR pre-operation OR pre-surgical or pre-surgery or presurgery or presurgical)

AND

psychopatholog* OR adjustment OR affective OR psychotic OR psychosis OR bipolar OR counsel* OR depression OR depressive OR dysthymic OR “Psychiatric Counseling” OR “Psychiatric evaluation” OR “seasonal affective disorder”

Search modes - Find all search terms

NUMBER OF RESULTS: 205

NUMBER OF RESULTS AFTER MANUAL FILTERING IN ENDNOTE TO REMOVE DUPLICATES, ANIMAL-ONLY STUDIES AND NON-RELEVANT MATERIAL: 55

Search updated 8/15/2014, number of results: 23

## RELATED ARTICLE SEARCH FOR MALIK AND COLLEAGUES' KEY ARTICLE

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed– 1/1/1990-12/12/2013

LANGUAGE:

English

SEARCH STRATEGY:

“RELATED ARTICLES” SEARCH ON THE FOLLOWING REFERENCE:

S. Malik, J. E. Mitchell, S. Engel, R. Crosby and S. Wonderlich (2013).”Psychopathology in bariatric surgery candidates: A review of studies using structured diagnostic interviews.” Compr Psychiatry. Oct 24

Search updated 8/15/2014, number of results: 3