# RESULTS

## LITERATURE FLOW

We identified 2890 unique citations from a combined electronic search of MEDLINE^®^ via PubMed^®^ (n = 982), PsycINFO^®^ (n = 1472), and Cochrane Library (n = 413) and a manual examination of references (n = 23); zero additional articles were identified from an updated search of relevant systematic reviews. After applying inclusion and exclusion criteria, 2824 articles were excluded at the title-and-abstract level. We retrieved 66 articles for full-text review and excluded 54. For data abstraction and evidence synthesis, we retained a total of 12 articles representing 9 unique studies. Figure 2 illustrates each step of our literature search process.

Figure 2 Literature flow diagram

*Article reference list includes additional references cited for background and methods plus Web sites relevant to key questions. Companion studies are articles containing additional data pertinent to the unique, primary studies that were abstracted.

## KQ 1 In general medical patients with somatic symptoms, what are the performance characteristics (e.g., sensitivity, specificity) of self-report questionnaires for diagnosing generalized anxiety disorder or panic disorder?

### Self-report Measures

We identified nine studies that validated eight self-report measures of GAD and PD in primary care and general medical settings. Of these, two measures were GAD specific: Anxiety Disorder Scale–Generalized Anxiety and the Generalized Anxiety Disorder-7.^34,35^ Three measures were PD specific: an unnamed 10-item questionnaire,36 the Patient Health Questionnaire module for panic disorder,18 and the Brief Panic Disorder Screen.37 Two measures were multicomponent: Primary Care Evaluation of Mental Disorders38 and Symptom Driven Diagnostic System–Primary Care.39,40 One measure addressed both GAD and PD: Beck Anxiety Inventory–Primary Care.41 All of the questionnaires were self-administered and did not require specialized equipment or trained personnel, making them suitable for patients to complete in a variety of settings.

#### Symptom Driven Diagnostic System-Primary Care (SDDS-PC)

The SDDS-PC is a two-stage instrument developed to diagnose mental disorders in primary care clinics. The first stage is a brief self-administered screen for six disorders including GAD and PD. Each positive screen requires further administration of a detailed diagnostic module. Among the instruments included in this review, the SDDS-PC is the only one that has been validated in more than one study; however, the versions tested in the two articles are slightly different. Leon and colleagues tested a 26-item scale with 4 items for GAD and 5 items for PD,39 whereas Broadhead and colleagues tested an earlier version with 3 items for anxiety and 2 for GAD.40

#### Primary Care Evaluation of Mental Disorders (PRIME-MD)

The PRIME-MD was developed in the early 1990s to diagnose common mental illnesses, including anxiety disorders, in medical populations. It is a multicomponent questionnaire with two stages, the first of which is a brief screen consisting of 26 items, of which 3 address anxiety. If the patient answers yes to any of these questions, the physician is then prompted to use a diagnostic module for that disorder.38 The two-step process takes 5 to 6 minutes in patients without a mental illness versus 11 to 12 minutes in those with a diagnosis. This was considered a barrier to use in routine clinical settings and subsequently led to the development of the Patient Health Questionnaire and Generalized Anxiety Disorder-7.

#### Patient Health Questionnaire (PHQ)

The PHQ is a three-page instrument that addresses depression, PD, other anxiety disorders, eating disorders, and alcohol abuse. After completion of the self-report form by the patient, the clinician can apply the abbreviated algorithm at the end of each page to make a diagnostic decision.18 Though the PHQ specifically addresses PD, it is not specific to GAD.

#### Generalized Anxiety Disorder-7 (GAD-7)

The GAD-7 is a seven-item questionnaire specific to the diagnosis of GAD. It was developed to be a short instrument that can be used in primary care settings. An affirmative answer on any of the seven primary questions requires the patient to answer one more question about the effect of symptoms on functioning at work, home, and relationships. The authors suggested that, in addition to diagnosing GAD, this instrument could be used for tracking the severity of symptoms since cut points of 5, 10, and 15 could be interpreted as mild, moderate, and severe level of anxiety.35

#### Beck Anxiety Inventory-Primary Care (BAI-PC)

The BAI-PC is an abbreviated version of the more commonly known Beck Anxiety Inventory.42 The seven items included in the BAI-PC are said to represent a “subjective dimension” of anxiety and include “unable to relax,” “fear of the worst happening,” “terrified,” “nervous,” “fear of losing control,” “fear of dying,” and “scared.” The authors proposed that not including somatic symptoms might help screen out medical patients without anxiety and thereby increase the specificity of the instrument.

#### Anxiety Disorder Scale-Generalized Anxiety (ADS-GA)

The ADS-GA was developed as an instrument to detect anxiety disorders in individuals 65 years of age and older. The scale is an 11-item questionnaire in a dichotomous Yes/No format. Early validation studies determined the optimum cutoff to be 4 or 5 positive responses out of a possible 11 items.43 Krasucki and colleagues validated this instrument in an outpatient geriatric population and developed a shortened version called the FEAR (frequency of anxiety; enduring nature of anxiety; alcohol or sedative use; restlessness or fidgeting). However, the shortened version has not been evaluated in an independent sample.34

#### Brief Panic Disorder Scale (BPDS)

The BPDS is a subscale of the 16-item Anxiety Sensitivity Inventory (ASI), a self-report measure used to assess sensitivity to the physical sensations associated with panic, such as heart racing and dizziness.44 The subscale was derived in a sample of patients from an anxiety disorders clinic.45 It consists of four items, all of which start with “It scares me when I …” and are followed by symptoms that include “feel shaky,” “feel faint,” “become short of breath,” and “heart beats rapidly.” Johnson and colleagues then validated this in a biracial primary care population.37

#### Unnamed 10-item questionnaire for PD

The 10-item instrument for the diagnosis of PD developed by Barsky and colleagues is unique in that it was derived in a sample of patients who were referred to an ambulatory electrocardiogram laboratory for the evaluation of palpitations. All of the other instruments were studied in unselected patients presenting to a general medical setting. The 10-item instrument was then validated in an independent sample of 124 patients referred for Holter monitoring of palpitations.36 This scale has not been studied in other populations, and so the performance might vary based on patient characteristics.

Table 2 summarizes the characteristics of the 8 self-report measures.

Table 2 Characteristics of 8 self-report measures for GAD and PD

Instrument | Number of items | Scope | Response format | Timeframe | Score range | Usual cut point | Literacy levels^a^ | Completion time | Tracking of symptoms
BAI-PC | 7 | GAD and PD | 4 items of symptom severity | Past 2 weeks to today | 0-21 | ≥ 5 | Easy | ≈ 1 minute46 | Unknown
PRIME-MD | 3 | Multiple components with GAD and PD | Yes or No | Past month | 0-3 | ≥ 1 | Easy | <1 minute | No
SDDS-PC | 5-PD | PD | Yes or No | Past month | 0-5 | Unclear | Easy | <2 minutes | Yes (scale has a separate longitudinal tracking module)
SDDS-PC | 4-GAD | GAD | Yes or No | 6 months | 0-5 | Unclear | Easy | <2 minutes | Yes (scale has a separate longitudinal tracking module)
GAD-7 | 7 | GAD | 4 frequency ratings: “Not at all,” “several days,” “more than half the days,” “nearly every day” | 2 weeks | 0-21 | 5 = mild 10 = moderate 15 = severe | Average | Unknown | Unknown
ADS-GA | 11 | GAD | Yes or No | Unknown | 0-11 | 4–5 | Easy | Unknown | Unknown
PHQ (panic module from original 3 page diagnostic form) | 5 questions (5^th^ has 11 subitems) | PD | Yes or No | 4 weeks | 0-5 | Yes on first 4 questions with yes on 4 of the 11 subitems for question 5 | Easy | < 1 for 42% 1 to 2 for 43% 3 to 5 for 13% > 5 for 3% | No
BPDS | 4 | PD | Symptom severity: “Very Little,” “A Little,” “Some,” “Much,” “Very Much” | None | 0-16 | ≥ 11 | Average | Unknown | Unknown
Unnamed scale | 10 | PD | Symptom severity: “not at all,” “a little bit,” “moderately,” “quite a bit,” “a great deal” | Unknown | 0-50 | > 21 | Average | Unknown | Unknown

a Easy indicated third- to fifth-grade reading level; average, sixth- to ninth-grade reading level.47

### Characteristics of Included Studies

Table 3 summarizes the characteristics of the nine studies included in this evidence synthesis. The sample sizes among the studies varied widely ranging from 56 to 3000. Other than one study that was conducted on patients attending a referral clinic for Holter monitoring,36 all other studies were conducted in general medical clinics. One study selected patients presenting with palpitations;36 all other studies recruited patients without regard to the presenting medical problem. None of the studies were conducted in VA hospitals or clinics; however, all but one of the studies were conducted in the U.S.

Table 3 Characteristics of 9 included studies

Study | Setting and patient selection | Sample characteristics^a^ | Prevalence | Instrument and threshold | Criterion standard | Quality rating
Beck et al., 1997^41^ | Primary care Unselected | N: 56 Age: 48.54 (15.52) Female: 73% | GAD or PD: 23% | BAI-PC 5 | DSM IIIR | III
Spitzer et al., 1994^38^ | Primary care Unselected | N: 431 Age:55 (16.5) Female: 60% | GAD or PD: 17.9% | PRIME-MD ≥ 1 | DSM IIIR | I
Broadhead et al.,1995(a)40 | Primary care Unselected | N: 388 Age: 39.4 (12.4) Female: 72% | GAD: 3.09% PD: 6.9% | SDDS-PC | DSM IIIR | I
Broadhead et al.,1995(b)40 | Primary care Unselected | N:257 Age: 40.3 (13.2) Female: 70% | GAD: 5.44% PD: 6.2% | SDDC-PC | DSM IIIR | I
Leon et al., 1996 39 | Primary care Unselected | N: 501 Age: 49.4 Female: 66% | GAD: 15.96% PD: 7.9% | SDDC-PC | DSM IV | I
Spitzer et al., 1999^18^ | Primary care Unselected | N: 585 Age: 46 (17.2) Female: 66% | PD: 7.0% | PHQ | DSM IIIR | I
Krasucki et al., 1999^34^ | Primary care Unselected | N: 40 Age: 72.6 (NR) Female: 64% | GAD: 15.0% | ADS-GA | ICD 10 | III
Barsky et al., 1997^36^ | Specialty clinic Palpitations | N: 124 Age: 47.36 (NR) Female: 57% | PD: 25.8% | Un-named instrument | DSM IIIR | II
Spitzer et al., 2006^35^ | Primary care Unselected | N: 965 Age: 47.4 (15.5) Female: 65% | GAD: 7.6% | GAD-7 | DSM IV | I
Johnson et al., 2007^48^ | Primary care Unselected | N: 295 Age: 54.1 (11.2) Female: 66% | PD: 13.9% | BPDS | DSM IV | I

a Reported Ns were calculated based on the number of patients who completed the criterion standard and not based on number enrolled in study.

All of the studies had a high proportion of women (≥ 60%), which might make the samples somewhat different from a predominantly male Veteran population. All but one study 34 reported the distribution of race, which was predominantly white but varied widely between studies (35 to 98%). In most of the studies, the screening instrument was self-administered. In one study in which 22 percent of the participants had not completed high school, a research assistant verbally administered the test to those who had difficulty reading.48 Seven studies reported educational achievement among the participants, and the proportion of patients who had completed high school ranged from 77.8 to 94 percent.

### Performance Characteristics of Self-report Measures

Table 4 shows performance characteristics of the self-report measures in the primary care setting (along with 95% confidence intervals). An ideal self-report measure has a high sensitivity (a high proportion of patients with an anxiety disorder have a positive self-report) and a high specificity (a high proportion of patients without an anxiety disorder have a negative self-report). Likelihood ratios are a measure of how useful the self-report is based on sensitivity and specificity. Values may range from 0 to infinity, with values above 1 increasing and values below 1 decreasing the likelihood of an anxiety disorder. The likelihood ratio positive indicates how much more likely a positive self-report comes from a patient with, rather than without, an anxiety disorder. The likelihood ratio negative indicates how much more likely a negative self-report comes from a patient with, rather than without, an anxiety disorder. When coupled with the pretest probability of disease, the likelihood ratio allows ready calculation of posttest probability of disease. In general, diagnostic tests with likelihood ratios ≥ 5 or ≤ 0.2 have large effects on the posttest probability of disease.

Table 4 Performance characteristics of self-report measures in primary care settings

Study | Instrument | Sensitivity | Specificity | Likelihood ratio positive | Likelihood ratio negative
GAD and PD
Spitzer et al., 1994^38^ | PRIME-MD | 0.93 (0.85 to 0.98) | 0.53 (0.48 to 0.58) | 1.99 (1.76 to 2.26) | 0.12 (0.05 to 0.29)
Beck et al, 1997^41^ | BAI-PC | 0.85 (0.55 to 0.98) | 0.81 (0.67 to 0.92) | 4.55 (2.33 to 8.86) | 0.19 (0.05 to 0.68)
GAD specific
Broadhead et al., 1995(a)40 | SDDS-PC | 0.92 (0.61 to 1.00) | 0.54 (0.49 to 0.59) | 1.99 (1.63 to 2.44) | 0.15 (0.02 to 1.01)
Broadhead et al., 1995(b)40 | SDDS-PC | 0.86 (0.57 to 0.98) | 0.60 (0.53 to 0.66) | 2.12 (1.63 to 2.76) | 1.12 (1.63 to 2.76)
Leon et al., 1996^39^ | SDDS-PC | 0.74 (0.63 to 0.83) | 0.82 (0.78 to 0.85) | 4.08 (3.21 to 5.20) | 0.32 (0.22 to 0.46)
Krasucki et al., 1999^34^ | ADS-GA | 0.40 (0.05 to 0.85) | 0.86 (0.70-0.95) | 2.88 (0.75 to 11.07) | 0.70 (0.34 to 0.46)
Spitzer et al., 2006^35^ | GAD-7 | 0.89 (0.79 to 0.95) | 0.82 (0.79 to 0.84) | 4.93 (4.20 to 5.80) | 0.13 (0.07 to 0.26)
PD specific
Spitzer et al., 1999^18^ | PHQ | 0.80 (0.65 to 0.91) | 0.99 (0.98 to 1.00) | 87.41 (36.06 to 211.88) | 0.20 (0.11 to 0.37)
Broadhead et al., 1995(a)40 | SDDS-PC | 0.78 (0.58 to 0.91) | 0.80 (0.76 to 0.84) | 3.90 (2.92 to 5.20) | 0.28 (0.14 to 0.56)
Broadhead et al., 1995(b)40 | SDDS-PC | 0.62 (0.35 to 0.85) | 0.83 (0.78 to 0.88) | 3.77 (2.34 to 6.05) | 0.45 (0.24 to 0.85)
Leon et al., 1996^39^ | SDDS-PC | 0.70 (0.53 to 0.83) | 0.91 (0.88 to 0.93) | 7.87 (5.51 to 11.23) | 0.33 (0.20 to 0.53)
Barsky et al., 1997^36^ | 10-item scale | 0.72 (0.53 to 0.86) | 0.71 (0.60 to 0.80) | 2.45 (1.67 to 3.60) | 0.40 (0.22 to 0.70)
Johnson et al., 2007^48^ | BPDS | 0.61 (0.44 to 0.76) | 0.29 (0.23 to 0.35) | 0.86 (0.66 to 1.11) | 1.36 (0.88 to 2.08)

The PRIME-MD had a relatively high sensitivity compared to its specificity, which is not surprising given that the screen has three broad questions intended to prompt further physician interview. Among the instruments that screen for GAD, the GAD-7 had good sensitivity and specificity with comparable likelihood ratios. However, this instrument has been validated in only one population.

The SDDS-PC has been validated in more than one population; however, the versions in the two studies are slightly different in that the study by Broadhead and colleagues40 tested the 16-item SDDS-PC with 2 questions for GAD and 3 for PD corresponding to the DSM-IIIR, whereas the study by Leon and colleagues39 tested a 26-item instrument under the same name with 4 questions for GAD and 5 for PD made to correspond to DSM-IV. Not surprisingly, the SDDS-PC showed variable performance characteristics depending on the version and the sample. The two samples (initial validation and cross validation) in the study by Broadhead and colleagues40 were significantly different in race, education, and marital status.

The ADS-GA was unique in that it was the only study conducted outside the U.S., and the population in the study was also substantially older, with a mean age of 72.6 years. The ADS-GA had low sensitivity (40%) for GAD, making its performance and study population an outlier in this group of studies.

Among the studies that examined instruments specific for panic disorder, the PHQ had the highest sensitivity and specificity with a very high positive predictive value and a moderately good negative predictive value. Other instruments, the BAI-PC, the 10-item scale, and the BPDS are not discussed further due to very small sample sizes and/or unimpressive performance characteristics.

### Examination of Heterogeneity and Statistical Pooling of Data

Because GAD and PD are two distinct illnesses with unique courses and differences in response to treatment, we did not attempt to statistically combine the studies; instead, we analyzed them in two groups: GAD-specific instruments and PD-specific instruments. However, for analysis purposes, we did combine the two studies that screened for both GAD and PD38,41 with both groups. We also conducted a sensitivity analysis without the above two studies to determine if they contributed significantly to heterogeneity.

For GAD, the test for heterogeneity (Cochran's Q) was statistically significant (p<0.001) for all 4 performance characteristics (sensitivity, specificity, positive predictive value, and negative predictive value). The I^2^ ranged from 78.3 to 97.2 percent, which indicated a high level of heterogeneity. Sensitivity analysis without the two nonspecific instruments did not significantly decrease the heterogeneity. Neither did repeating the analysis without the study by Krasucki and colleagues,34 which, on visual inspection of plots, appeared to be an outlier.

To further explore heterogeneity, we examined if a threshold effect was present. The Spearman correlation coefficient between the logit sensitivity and logit of 1-specificity was 0.786 (p = 0.036), which suggests a threshold effect. A threshold effect can occur when different studies examining an instrument use different thresholds for diagnosis, resulting in varying sensitivities and specificities. However, it is unlikely here since the studies included were examining different instruments, which in itself can contribute to heterogeneity. Further, partial verification bias and differences in samples and settings can also contribute to heterogeneity. In this analysis, all studies were conducted with unselected patients from primary care settings, but diagnostic standards and assessment methods varied across studies, which could have contributed to a threshold effect.

For PD, the test for heterogeneity (Cochran's Q) was statistically significant (p<0.001) and I^2^ ranged from 71.4 to 99.0 percent, again indicating a high level of heterogeneity. Sensitivity analyses without the nonspecific instruments did not significantly reduce heterogeneity. We again explored the presence of a threshold effect, but in this case, the Spearman correlation coefficient was −0.071 (p = 0.867), indicating that a threshold effect is unlikely to contribute to heterogeneity. Because the patients in the study by Barsky and colleagues36 were significantly different in that they were all referred for Holter monitoring of palpitations and had a high prevalence of PD, we conducted a sensitivity analysis without this study but did not find a change in the heterogeneity. Given the high degree of heterogeneity, we did not statistically combine the results from the all studies to yield summary estimates of sensitivity and specificity. Instead, we plotted the results on a summary receiver operating characteristic curve (SROC) for each disorder (Figures 3 and 4). A summary ROC displays the trade-off between sensitivity and specificity. Several useful statistical properties are reported in the figures, including the area under the curve (AUC) and the Q*. The AUC is a measure of the questionnaire's ability to discriminate between those with and without an anxiety disorder. A value of 0.5 is no better than chance, while a value of 1.0 represents perfect diagnostic test discrimination; tests with values greater than 0.80 are generally considered to have good discriminate properties. The Q* statistic is the point on the SROC where sensitivity equals specificity. As can be seen in Figures 3 and 4, the questionnaires collectively have good overall test performance.

Figure 3 SROC curve for GAD measures

Figure 4 SROC curve for PD measures

We did an exploratory analysis of the three studies that validated the SDDS-PC. Heterogeneity for GAD was moderate to high, and there was a high threshold effect with a Spearman correlation coefficient of 1 (p < 0.001). However, for PD, the heterogeneity was minimal for sensitivity (Cochran's Q = 1.19, df = 2, p = 0.55; I^2^ of 0). Similarly, the heterogeneity for the negative likelihood ratio was also low (Cochran's Q = 1.09, df=2, p = 0.58; I^2^ = 0). Heterogeneity for other operating characteristics was high. Overall threshold effect was small, with the Spearman correlation coefficient of 0.5 (p = 0.67). Therefore, we statistically combined the results for sensitivity and negative likelihood ratio of the SDDC-PC for PD using a random effects model. The pooled sensitivity for the SDDS-PC was 0.71 (95% CI 0.60 to 0.80) and the pooled negative likelihood ratio was 0.35 (95% CI 0.25 to 0.48) (Figure 5).

Figure 5 Forest plot of pooled sensitivity for studies that tested the SDDS-PC for PD

### Quality of Evidence for KQ 1

The quality of evidence for each of the studies was evaluated using the modified QUADAS. A summary graph of the quality is provided in Figure 6. All included studies gave clearly described inclusion criteria for patients, used accurate reference standards, and conducted the reference standard within a reasonable time. The study authors decided that administering the reference standard within a month of the index test would not affect the validity given that both PD and GAD exist for longer periods of time.

Figure 6 QUADAS summaries for KQ 1

Most studies did not choose a cutoff a priori since many studies combined both the development and the validation of the scale—thus there was no established cutoff the investigators could use. This is a weakness because many of these validation studies have not been replicated. Also, many of the studies did not confirm the diagnosis using the reference standard in all, or in a random sample, of the patients, which could have contributed to partial verification bias.

## KQ 2 For questionnaires evaluated in KQ 1, which measures are most feasible to use in primary care settings? Specifically, what is the reading comprehension level, time required to complete, response format, and compatibility with telephone administration?

### Studies of Efficacy

Based on considerations of feasibility, there is limited evidence to recommend one screening tool over another. Instrument characteristics regarding feasibility are summarized in Table 2. Most of the instruments are brief, with the number of questions ranging from 3 to 11. The GAD-7, BPDS, and 10-item PD instrument are at an average reading level (sixth to ninth grade), and the rest are at an easy reading level (third to fifth grade). The PRIME-MD has been validated for telephone administration and includes screening and diagnostic assessments for multiple common mental illnesses; the 3-item screening measure for anxiety disorders takes less than 1 minute to complete.49 The average time taken to complete all sections of the PRIME-MD diagnostic interview, triggered by positive responses on the associated screening component, was 8.4 minutes, which in a busy clinic was found to be too high to be practical.38 The following observations are about selected instruments that may be promising based on our qualitative assessment of their feasibility.

For PD, the panic module of the PHQ is a short, self-report instrument with reading and comprehension at the third- to fifth-grade level and a simple yes/no response format. In the initial validation study, 42 percent of patients took less than 1 minute to complete the questionnaire, 43 percent took 2 to 3 minutes, and 13 percent took more than 5 minutes. We did not identify any studies where the feasibility of telephone administration of the PHQ was studied. However, both the yes/no and the 4-item Likert response formats of the PHQ for depression have been used successfully with telephone administration.50 Considering feasibility as a function of performance of the instrument, in an average primary care clinic with a 7 percent prevalence of PD, a clinician seeing 100 patients per week can expect 6 to 7 patients to screen positive for PD, while 1 patient might not be identified by the instrument. Of patients who screen positive, almost all will have PD. One disadvantage is that the PHQ panic module, unlike the PHQ-9 for depression, has been studied rigorously in only one large sample.18

For generalized anxiety disorder, the GAD-7 is a short, well-performing instrument that assesses the severity of DSM -IV criteria symptoms over the past 2 weeks. Unlike the dichotomized response format of the panic module of the PHQ, the GAD-7 has four response options reflecting increased levels of severity. Both the 2-week time period and the graded response format might be useful in tracking response to treatment; however, responsiveness has not been studied formally. In a primary care clinic with GAD prevalence of 7.6 percent, 23 out of 100 patients will screen positive for GAD, while 1 patient with GAD might not be identified by the instrument. Of patients who screen positive, 16 to 17 will not have GAD after a diagnostic evaluation (false positives) and 6 to 7 will be true positives. Similar to the PHQ for panic, the GAD-7 has been validated with a diagnostic standard in only one sample.35

The SDDS-PC has the advantage of being a single instrument for both GAD and PD along with other mental disorders, which can be useful in a busy primary care setting. However, the combined sensitivity of the instrument is lower than the GAD-7 and PHQ. Further, the SDDS then requires confirmation through a nurse-administered computer module that is entered using the SDDS-PC software. No recent studies of the SDDS-PC have been published, and it is uncertain if the needed software has been updated for modern computer operating systems. We did not identify any studies that examined its compatibility with telephone administration.

### Quality of Evidence for KQ 2

We did not find studies that directly addressed the feasibility of the administration of the various instruments included in this review. Our assessment is based on the primary validation studies for KQ 1, discussed previously. Further, the assessment of reading level was not provided in the primary studies but was assessed by the authors using computer software.

## KQ 3 For questionnaires evaluated in KQ 1, do the performance characteristics vary by gender, race, age group, or setting?

Among the self-report measures evaluated, none of the GAD studies and only one PD study reported a subgroup analysis. Johnson and colleagues48 compared Caucasian to African-American patients, while no studies reported subgroup analyses by gender, age group, or setting for PD. The absence of such data suggests that additional research is needed to determine if the various screening measures perform similarly among different subpopulations.

The report by Johnson and colleagues48 was good quality and differed from other studies only in the fact that the screening instrument was administered verbally to an unspecified number of participants who had difficulty reading. In the subgroup analysis, the study by Johnson and colleagues48 compared the performance characteristics of the BPDS for 216 Caucasian versus 79 African-American primary care patients. Sensitivity data indicated that the questionnaire performed similarly in the two groups (Caucasian = .60, African American = .63, χ^2^[1, N = 295] = 0.03, p = .87). The questionnaire's specificity, however, significantly differed between the two groups (Caucasian = .25, African American = .60, χ^2^[1, N = 295] = 0.75, p = .03). These results indicate that the BPDS performed better among Caucasians because at the optimal cutoff of 10, there were more false positives among African Americans. Table 4 displays the sensitivity, specificity, positive likelihood ratio, and negative likelihood ratio from this study.

Qualitatively, there were differences in sensitivity and specificity among the two samples in the initial validation and cross-validation samples in the study by Broadhead and colleagues, which had different ethnic distributions.40 The instrument, methods and quality of the two studies were the same. The initial validation sample was 97.9 percent white and 0.3 percent black, while the cross-validation sample had 71.9 percent white and 26 percent black (p < 0.001). The sensitivity and specificity were 0.92, 0.54 and 0.86, 0.60 respectively. However, the two samples also varied significantly in terms of education and marital status; therefore, one cannot conclude that the differences are exclusively due to the racial distribution.