# REFERENCES

1 Hoffman DL, Dukes EM, Wittchen HU. Human and economic burden of generalized anxiety disorder. Depress Anxiety. 2008;25(1):72-90. [pmid: 17146763].
2 Schonfeld WH, Verboncoeur CJ, Fifer SK, et al. The functioning and well-being of patients with unrecognized anxiety disorders and major depressive disorder. J Affect Disord. 1997;43(2):105-19. [pmid: 9165380].
3 American Psychiatric Association Task Force on DSM-IV. Diagnostic and statistical manual of mental disorders: DSM-IV-TR. 4. Washington, DC. American Psychiatric Association. 2000.
4 Wittchen HU, Zhao S, Kessler RC, et al. DSM-III-R generalized anxiety disorder in the National Comorbidity Survey. Arch Gen Psychiatry. 1994;51(5):355-64. [pmid: 8179459].
5 Kessler RC, McGonagle KA, Zhao S, et al. Lifetime and 12-month prevalence of DSM-III-R psychiatric disorders in the United States. Results from the National Comorbidity Survey. Arch Gen Psychiatry. 1994;51(1):8-19. [pmid: 8279933].
6 Byers AL, Yaffe K, Covinsky KE, et al. High occurrence of mood and anxiety disorders among older adults: The National Comorbidity Survey Replication. Arch Gen Psychiatry. 2010;67(5):489-96. [pmid: 20439830].
7 Kroenke K, Spitzer RL, Williams JB, et al. Anxiety disorders in primary care: prevalence, impairment, comorbidity, and detection. Ann Intern Med. 2007;146(5):317-25. [pmid: 17339617].
8 Adler DA, Possemato K, Mavandadi S, et al. Psychiatric status and work performance of veterans of Operations Enduring Freedom and Iraqi Freedom. Psychiatr Serv. 2011;62(1):39-46. [pmid: 21209298].
9 Hoge CW, Castro CA, Messer SC, et al. Combat duty in Iraq and Afghanistan, mental health problems, and barriers to care. N Engl J Med. 2004;351(1):13-22. [pmid: 15229303].
10 Bridges KW, Goldberg DP. Somatic presentation of DSM III psychiatric disorders in primary care. J Psychosom Res. 1985;29(6):563-9. [pmid: 4087223].
11 Kirmayer LJ, Robbins JM, Dworkind M, et al. Somatization and the recognition of depression and anxiety in primary care. Am J Psychiatry. 1993;150(5):734-41. [pmid: 8480818].
12 Tyrer P, Baldwin D. Generalised anxiety disorder. Lancet. 2006;368(9553):2156-66. [pmid: 17174708].
13 Nutting PA, Rost K, Dickinson M, et al. Barriers to initiating depression treatment in primary care practice. J Gen Intern Med. 2002;17(2):103-11. [pmid: 11841525].
14 Rost K, Nutting P, Smith J, et al. The role of competing demands in the treatment provided primary care patients with major depression. Arch Fam Med. 2000;9(2):150-4. [pmid: 10693732].
15 Rubenstein LV, Williams JW Jr., Danz M, et al. 2009.
16 Roy-Byrne P, Craske MG, Sullivan G, et al. Delivery of evidence-based treatment for multiple anxiety disorders in primary care: a randomized controlled trial. JAMA. 2010;303(19):1921-8. [pmid: 20483968].
17 Williams JW Jr, Gerrity M, Holsinger T, et al. Systematic review of multifaceted interventions to improve depression care. Gen Hosp Psychiatry. 2007;29(2):91-116. [pmid: 17336659].
18 Spitzer RL, Kroenke K, Williams JB. Validation and utility of a self-report version of PRIME-MD: the PHQ primary care study. Primary Care Evaluation of Mental Disorders. Patient Health Questionnaire. JAMA. 1999;282(18):1737-44. [pmid: 10568646].
19 World Health Organization. AUDIT. The Alcohol Use Disorders Identification Test: Guidelines for Use in Primary Care. Available at: http://whqlibdoc.who.int/hq/2001/who_msd_msb_01.6a.pdf. June 16, 2011.
20 Rollman BL, Belnap BH, Mazumdar S, et al. A randomized trial to improve the quality of treatment for panic and generalized anxiety disorders in primary care. Archives of General Psychiatry. 2005;62(12):1332-41. [pmid: 16330721].
21 Kapczinski F, Lima MS, Souza JS, et al. Antidepressants for generalized anxiety disorder. Cochrane Database Syst Rev. 2003;(2):CD003592. [pmid: 12804478].
22 Furukawa TA, Watanabe N, Churchill R. Combined psychotherapy plus antidepresants for panic disorder with or without agoraphobia. Cochrane Database Syst Rev. 2007;(1):CD004364. [pmid: 17253502].
23 Haynes RB, Wilczynski NL. Optimal search strategies for retrieving scientifically strong studies of diagnosis from Medline: analytical survey. BMJ. 2004;328(7447):1040. [pmid: 15073027].
24 Wilczynski NL, Haynes RB. EMBASE search strategies for identifying methodologically sound diagnostic studies for use by clinicians and researchers. BMC Med. 2005;3:7. [pmid: 15796772].
25 Hsiao CJ, Cherry DK, Beatty PC, et al. National Ambulatory Medical Care Survey: 2007 summary, Natl Health Stat Report. 2010;(27):1-32. Available at: http://www.cdc.gov/nchs/data/nhsr/nhsr027.pdf. August 8, 2011.
26 Bossuyt PM, Reitsma JB, Bruns DE, et al. The STARD statement for reporting studies of diagnostic accuracy: explanation and elaboration. Ann Intern Med. 2003;138(1):W1-12. [pmid: 12513067].
27 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960].
28 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Med Res Methodol. 2006;6:9. [pmid: 16519814].
29 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
30 Zamora J, Abraira V, Muriel A, et al. Meta-DiSc: a software for meta-analysis of test accuracy data. BMC Med Res Methodol. 2006;6:31. [pmid: 16836745].
31 Wallace BC, Schmid CH, Lau J, et al. Meta-Analyst: software for meta-analysis of binary, continuous and diagnostic data. BMC Med Res Methodol. 2009;9:80. [pmid: 19961608].
32 Kincaid JP, Fishburne RP, Rogers RL, et al. Derivation of New Readability Formulas (Automated Readability Index, Fog Count and Flesch Reading Ease Formula) for Navy Enlisted Personnel. Naval Technical Training Command Millington Tenn Research Branch. 1975.
33 Schunemann HJ, Oxman AD, Brozek J, et al. Grading quality of evidence and strength of recommendations for diagnostic tests and strategies. BMJ. 2008;336(7653):1106-10. [pmid: 18483053].
34 Krasucki C, Ryan P, Ertan T, et al. The FEAR: A rapid screening instrument for generalized anxiety in elderly primary care attenders. Int J Geriatr Psychiatry. 1999;14(1):60-68. [pmid: 10029937].
35 Spitzer RL, Kroenke K, Williams JB, et al. A brief measure for assessing generalized anxiety disorder: the GAD-7. Arch Intern Med. 2006;166(10):1092-7. [pmid: 16717171].
36 Barsky AJ, Ahern DK, Delamater BA, et al. Differential diagnosis of palpitations. Preliminary development of a screening instrument. Arch Fam Med. 1997;6(3):241-5. [pmid: 9161349].
37 Johnson MR, Hartzema AG, Mills TL, et al. Ethnic differences in the reliability and validity of a Panic Disorder Screen. Ethn Health. 2007;12(3):283-96. [pmid: 17454101].
38 Spitzer RL, Williams JB, Kroenke K, et al. Utility of a new procedure for diagnosing mental disorders in primary care. The PRIME-MD 1000 study. JAMA. 1994;272(22):1749-56. [pmid: 7966923].
39 Leon AC, Olfson M, Weissman MM, et al. Brief screens for mental disorders in primary care. J Gen Intern Med. 1996;11(7):426-30. [pmid: 8842936].
40 Broadhead WE, Leon AC, Weissman MM, et al. Development and validation of the SDDS-PC screen for multiple mental disorders in primary care. Arch Fam Med. 1995;4(3):211-9. [pmid: 7881602].
41 Beck AT, Steer RA, Ball R, et al. Use of the Beck Anxiety and Depression Inventories for primary care with medical outpatients. Assessment. 1997;4(3):211-219.
42 Beck AT, Epstein N, Brown G, et al. An inventory for measuring clinical anxiety: psychometric properties. J Consult Clin Psychol. 1988;56(6):893-7. [pmid: 3204199].
43 Wing JK. A technique for studying psychiatric morbidity in in-patient and out-patient series and in general population samples. Psychol Med. 1976;6(4):665-71. [pmid: 1005581].
44 Reiss S, Peterson RA, Gursky DM, et al. Anxiety sensitivity, anxiety frequency and the prediction of fearfulness. Behav Res Ther. 1986;24(1):1-8. [pmid: 3947307].
45 Apfeldorf WJ, Shear MK, Leon AC, et al. A brief screen for panic disorder. Journal of Anxiety Disorders. 8(1):71-78.
46 Mori DL, Lambert JF, Niles BL, et al. The BAI–PC as a Screen for Anxiety, Depression, and PTSD in Primary Care. Journal of Clinical Psychology in Medical Settings. 2003;10(3):187-192.
47 Gunning R. The technique of clear writing. Rev. ed. New York. McGraw-Hill. 1968.
48 Johnson MR, Hartzema AG, Mills TL, et al. Ethnic differences in the reliability and validity of a Panic Disorder Screen. Ethn Health. 2007;12(3):283-96. [pmid: 17454101].
49 Kobak KA, Taylor LH, Dottl SL, et al. A computer-administered telephone interview to identify mental disorders. JAMA. 1997;278(11):905-10. [pmid: 9302242].
50 Pinto-Meza A, Serrano-Blanco A, Penarrubia MT, et al. Assessing depression in primary care with the PHQ-9: can it be carried out over the telephone?. J Gen Intern Med. 2005;20(8):738-42. [pmid: 16050884].
51 Anonymous. Generalised anxiety disorder and panic disorder (with or without agoraphobia) in adults: management in primary, secondary and community care (partial update). National Clinical Guideline Number 113. National Collaborating Centre for Mental Health and the Royal College of General Practitioners. Commissioned by the National Institute for Health and Clinical Excellence. Available at: http://www.nice.org.uk/niceme-dia/live/13314/52667/52667.pdf. June 13, 2011.
52 Hunot V, Churchill R, Silva de Lima M, et al. Psychological therapies for generalised anxiety disorder. Cochrane Database Syst Rev. 2007;(1):CD001848. [pmid: 17253466].
53 Bakker A, van Balkom AJ, Spinhoven P. SSRIs vs. TCAs in the treatment of panic disorder: a meta-analysis. Acta Psychiatr Scand. 2002;106(3):163-7. [pmid: 12197851].
54 Otto MW, Tuby KS, Gould RA, et al. An effect-size analysis of the relative efficacy and tolerability of serotonin selective reuptake inhibitors for panic disorder. Am J Psychiatry. 2001;158(12):1989-92. [pmid: 11729014].
55 Clark DM, Salkovskis PM, Hackmann A, et al. Brief cognitive therapy for panic disorder: a randomized controlled trial. J Consult Clin Psychol. 1999;67(4):583-9. [pmid: 10450630].
56 Carlbring P, Nilsson-Ihrfelt E, Waara J, et al. Treatment of panic disorder: live therapy vs. self-help via the Internet. Behav Res Ther. 2005;43(10):1321-33. [pmid: 16086983].
57 American Psychiatric Association. DSM 5 Development. Available at: http://www.dsm5.org/ProposedRevision/Pages/proposedrevision.aspx?rid=167. June 17, 2011.
58 Tatsioni A, Zarin DA, Aronson N, et al. Challenges in systematic reviews of diagnostic technologies. Ann Intern Med. 2005;142(12 Pt 2):1048-55. [pmid: 15968029].
59 Pilkonis PA, Choi SW, Reise SP, et al. Item Banks for Measuring Emotional Distress From the Patient-Reported Outcomes Measurement Information System (PROMIS(R)): Depression, Anxiety, and Anger. Assessment. 2011.
60 Mohlman J, Bryant C, Lenze EJ, et al. Improving recognition of late life anxiety disorders in Diagnostic and Statistical Manual of Mental Disorders, Fifth Edition: observations and recommendations of the Advisory Committee to the Lifespan Disorders Work Group. Int J Geriatr Psychiatry. 2011.