# METHODS

## TOPIC DEVELOPMENT

This review was commissioned by the VA's Evidence-based Synthesis Program. The topic was nominated after a formal topic nomination and prioritization process that included representatives from the VA Office of Mental Health Services, Health Services Research and Development, Mental Health QUERI, and Primary Care–Mental Health Integration Program. We further developed and refined the key questions (KQs) for this review based on a preliminary review of published peer-reviewed literature in consultation with VA and non-VA experts to select patients, measures, outcomes, and settings addressed in this review.

The final KQs were:

KQ 1 In general medical patients with somatic symptoms, what are the performance characteristics (e.g., sensitivity, specificity) of self-report questionnaires for diagnosing generalized anxiety disorder or panic disorder?
KQ 2 For questionnaires evaluated in KQ 1, which measures are most feasible to use in primary care settings? Specifically, what is the reading comprehension level, time required to complete, response format, and compatibility with telephone administration?
KQ 3 For questionnaires evaluated in KQ 1, do the performance characteristics vary by gender, race, age group, or setting?

## ANALYTIC FRAMEWORK

We developed and followed a standard protocol for all steps of this review. Our approach was guided by the analytic framework shown in Figure 1.

Figure 1 Analytic framework

## SEARCH STRATEGY

We searched MEDLINE^®^ (via PubMed^®^), PsycINFO^®^, and the Cochrane Library for studies comparing self-report measures of GAD and PD with an acceptable criterion standard from January 1980 through December 2010. We chose 1980 to coincide with the publication of DSM-III so that the criterion standards used would be consistent with those used in current clinical practice. We limited the search to articles involving human subjects 18 years of age and older and published in the English language. We combined terms for the disorders with a validated search filter for retrieving articles on the diagnosis of health disorders.23,24 Our final search terms included generalized anxiety disorder, panic disorder, questionnaires, screening, sensitivity, specificity, likelihood, medical history taking, and accuracy as well as terms for individual screening tools that were identified during our initial review of the search results (Appendix A).

We developed our search strategy in consultation with a master librarian. We supplemented electronic searching by examining the bibliographies of review articles, systematic reviews, and included studies. We also consulted experts in the field.

## STUDY SELECTION

Using prespecified inclusion and exclusion criteria, two reviewers assessed titles and abstracts for relevance. Full-text articles, identified by either reviewer as potentially relevant, were retrieved for further review. Each article retrieved was examined by two reviewers against the eligibility criteria in Appendix B; disagreements were resolved by discussion or by a third reviewer. Studies excluded at the full-text review stage are listed with the reasons for exclusion in Appendix C.

Although KQ 1 was developed to focus on general medical patients with somatic symptoms, we chose to include studies with unselected patients presenting to general medical settings. We broadened the population criteria because few studies addressed only patients with specific somatic symptoms, and we reasoned that somatic symptoms were common (even if not specifically documented) in unselected general medical patients.25 To identify studies most applicable to the Veteran population in the U.S., we included studies that examined measures in English or Spanish and were conducted in North America, Western Europe, New Zealand, or Australia. Detailed eligibility criteria are described in Table 1.

Table 1 Summary of inclusion and exclusion criteria

Study characteristic | Inclusion criteria | Exclusion criteria
Study design | Prospective comparison of an anxiety questionnaire to a reference standard | Case control studies that select patients with known disease and compare to healthy controls
Population | Adults ≥18 in general medical clinics with or without somatic symptoms. | Study populations of patients with preexisting mental health diagnosis
Instrument | Self-report instrument used to measure GAD or PD that is feasible to use in a medical setting without need for specialized equipment | Instruments requiring interviewer administration
Reference standard | Criteria based on DSM III or later; ICD 9 or later | Studies without an independent criterion standard
Outcome | Study reports a measure of sensitivity/specificity or data to derive an n*k table to validate operating characteristics. | Data to calculate sensitivity or specificity not provided
Setting | Primary care clinics including general internal medicine, family medicine and geriatrics; general medical and selected specialty medical settings (e.g., emergency departments, cardiology, gastrointestinal clinics, rheumatology and women's health) | Highly specialized clinics (e.g., memory disorder clinic) and psychiatric or mental health clinics

## DATA ABSTRACTION

We abstracted data pertinent to the KQs into a data abstraction form (Appendix D). Key data included:

- study design
- setting
- population characteristics
- subject eligibility and exclusion criteria
- number of subjects
- details about the index test and criterion standard and their application
- psychiatric and medical comorbidities of the sample and outcomes

Data elements selected for abstraction were informed by the principles outlined by the Standards for Reporting of Diagnostic Accuracy (STARD).26 These elements included descriptors to assess applicability (e.g., setting, sample characteristics, anxiety disorder prevalence) and quality elements (e.g., recruitment method, blinding, reference standard, sample size). When provided, raw data for the n*k table was abstracted, and when not provided, data were derived from other performance characteristics such as sensitivity and specificity.

We abstracted data for all relevant thresholds when data for more than one threshold of the index test were reported. If data were analyzed for subgroups based on race or sex, we abstracted them in separate n*k tables to address KQ 3. Performance characteristics such as sensitivity and specificity were recalculated by each investigator performing the abstraction to validate the data. When results were adjusted for the sampling design (e.g., partial verification of the criterion based diagnosis), we use the adjusted results.

All data abstractions were confirmed by a second reviewer. Disagreements were resolved by consensus or by obtaining a third reviewer's opinion when consensus could not be reached. Further, one author independently abstracted and validated all the n*k tables to check for accuracy.

## QUALITY ASSESSMENT

We adopted a two-step approach to rate the quality of the evidence. First, we applied the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) criteria for each study. QUADAS is a 14-item tool that was developed to assess the quality of diagnostic accuracy studies included in systematic reviews so that appropriate conclusions can be drawn in the context of potential biases.27,28 Each item has three possible answers: Yes, No, and Unclear. The QUADAS criteria were applied for each study by the reviewer abstracting the article; this initial assessment was then overread by a second reviewer. Disagreements were resolved between the two reviewers, or when needed, by arbitration from a third reviewer.

To make QUADAS most relevant to studies of self-report tests for anxiety disorders, we modified question number 12 of the tool to ask: “Was the cutoff point for the test chosen a priori?” The rationale for this is many psychiatric scales intended for diagnostic purposes can have markedly different performance characteristics based on the cutoff used, with sensitivity and specificity changing in opposite directions. Not choosing the cutoff a priori, ideally based on prior research, can introduce bias and result in poor replicability in subsequent samples. The QUADAS criteria with our modification are detailed in Appendix E.

We then assigned a level of evidence for each study based on the elements covered in the QUADAS criteria. The levels of evidence ranged from I to V, with I being the highest level of evidence with a low risk of bias and V being the lowest level of evidence with a high risk for overestimating the accuracy of the test. The above assessment of quality is recommended by the Rational Clinical Exam series in the Journal of the American Medical Association (http://jama.ama-assn.org/cgi/collection/rational_clinical_exam). We also assessed studies for applicability to U.S. Veterans.

## DATA SYNTHESIS

We critically analyzed studies to compare their characteristics, methods, and findings. Data derived from the studies for n*k tables were used to calculate performance measures (e.g., sensitivity, specificity) for each individual study. We then explored heterogeneity among the studies using Cochran's Q and the I^2^, which describes the percentage of total variation across studies that is due to heterogeneity rather than to chance.29 Heterogeneity was categorized as low, moderate, or high based on I^2^ values of 25 percent, 50 percent, and 75 percent respectively. We also plotted study outcomes on a graph and visually evaluated the variation in study results. To further explore heterogeneity, we examined whether a threshold effect was present. A strong positive correlation between the sensitivities (and 1-specificities) is suggestive of a threshold effect. This is calculated as a Spearman correlation coefficient between the logit sensitivity and logit of 1-specificity. In the absence of a threshold effect, data were pooled, when statistically appropriate, using a random effects model. When a threshold effect was present, we analyzed the data using a summary receiver operating characteristic (ROC) curve.

Because GAD and PD are two distinct clinical entities, we did not attempt to combine the studies reporting on instruments that were specific to one or the other. Instead, we grouped them into two categories, studies on instruments specific for GAD and studies on instruments specific for PD, for analyses of heterogeneity. When an instrument was nonspecific and screened for both GAD and PD, we included it in both groups. When studies reported data to derive n*k tables by race or ethnicity, we calculated performance characteristics for each group for comparison.

Outliers were defined as studies that were markedly different from other included studies, due to either methodological or sample characteristics, or if they were significant outliers on visual inspection of forest plots of the operating characteristics. When we observed significant heterogeneity in operating characteristics, we recomputed summary estimates and test statistics after outliers were removed. Analysis was conducted using the open source software Meta-Disc, version 1.4 (Unit of Clinical Biostatistics, Ramón y Cajal Hospital, Madrid, Spain)30for all analyses except when we statistically combined data using a random effects model for which we used MetaAnalyst version Beta 3.13 (Tufts Medical Center).31

Because reading levels were not reported, we determined the reading level for each questionnaire using the Flesch-Kincaid Grade level readability formula through the corresponding Microsoft Word application.32

## RATING THE BODY OF EVIDENCE

In addition to rating the quality of individual studies, we evaluated the overall quality of the evidence for each KQ as proposed by the GRADE Working Group.33 In brief, the GRADE approach requires assessment of four domains: risk of bias, consistency, directness, and precision. Additional domains are to be used when appropriate. These domains were considered qualitatively, and two reviewers assigned a summary rating after discussion as High, Moderate, Low, or Insufficient strength of evidence according to the following criteria:

- High—Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate—Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low—Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence on an outcome is absent or too weak, sparse, or inconsistent to estimate an effect.

In some cases, high, moderate, or low ratings were not possible or imprudent to make. In these situations, a grade of Insufficient was assigned.33

## PEER REVIEW

A draft version of the report was reviewed by technical experts and clinical leadership, and their comments are provided in Appendix F.