# INTRODUCTION

Anxiety disorders are a major public health concern associated with functional impairment and increased use of the health care system.1,2 Two of the more common anxiety disorders are generalized anxiety disorder (GAD) and panic disorder (PD), which if identified, can be treated successfully with medications or psychotherapy. GAD is characterized by at least 6 months of persistent and excessive anxiety and worry that is difficult to control and is accompanied by three of six additional symptoms: restlessness, fatigue, decreased concentration, irritability, muscle tension, and sleep disturbance.3 PD, on the other hand, is episodic in nature and characterized by recurrent and unexpected panic attacks—periods of intense fear or terror associated with autonomic arousal such as breathlessness, chest pain, or fear of losing control—that become a cause of persistent concern in the patient.3

In community samples, GAD has a lifetime prevalence of 5.1 percent in the U.S. population aged 15 to 54 years.4 The prevalence of PD in the National Comorbidity Survey was 2.3 percent in the 12-month period prior to the interview and 3.5 percent over one's lifetime.5 The same study found that in the 12-month period preceding the interview, anxiety disorders (17%) were more likely to occur when compared to other common mental illnesses such as substance abuse (11%) and affective disorders (11%), indicating that anxiety disorders are more chronic in nature.5 In the sample of participants aged 55 years or older, the 12-month prevalence of GAD was 2 percent, and PD was found to be 1.3 percent.6 The prevalence of these disorders in primary care populations is higher than in community samples, with rates for GAD at 7.6 percent and PD at 6.8 percent.7

Among Operation Enduring Freedom and Operation Iraqi Freedom (OEF/OIF) Veterans referred for further behavioral health assessment based on preliminary screening, the incidence for GAD was 4.2 percent and for PD, 8 percent. Further, both disorders were significantly associated with limitations on work performance across multiple domains, thus affecting a Veteran's ability to maintain gainful employment and successfully reintegrate into civilian life.8 The main barrier to receiving mental health treatment among Veterans is stigma: 65 percent of Veterans who met screening criteria for a mental disorder stated, “I would be seen as weak.”9 Besides stigma-related reasons, more pragmatic concerns, such as difficulty scheduling appointments or getting time off from work, were high on the list.9

## BACKGROUND

Many patients with anxiety disorders present to their primary care doctors.7 However, almost half of the patients with an anxiety disorder are not diagnosed or treated. One obstacle in the diagnosis of anxiety disorders is the somatic presentation.10,11 In addition to anxiety and worry, the DSM-IV TR (text revision) includes symptoms such as restlessness, being easily fatigued, muscle tension, and sleep disturbance as diagnostic criteria for GAD—symptoms that might be associated with other common physical illnesses.3 Similarly, the DSM-IV TR defines a panic attack as a discrete period of discomfort where 4 out of 13 symptoms are present; however, many of these symptoms—palpitations, sweating, trembling or shaking, shortness of breath, feeling of choking, chest pain or discomfort, nausea or abdominal distress, feeling dizzy, unsteady, lightheaded or faint, paresthesias, chills or hot flushes—could be considered symptoms of other medical illnesses. In the Veteran population, symptoms of GAD and PD might also be present in patients with other mental illnesses such as substance abuse, PTSD, and depression. As one author describes, anxiety is a relatively easy symptom to elicit in medical settings; the diagnostic difficulty lies in the interpretation.12 In addition to identifying anxiety disorders that may present with physical symptoms, screening and treatment have the potential to improve patient outcomes.

Many of the barriers to the recognition, diagnosis, and effective treatment of GAD and PD parallel the quality gaps identified in the management of patients with depressive disorders.13,14 Over the past decade, models of care that included screening and integration between primary care and mental health professionals have been shown to improve outcomes for patients with depression or anxiety disorders.15-17 The VA has embraced these integrated-care models and employs systematic screening for depression, posttraumatic stress disorder, and alcohol-related disorders. Patients referred to the integrated-care programs are also screened for comorbid conditions, including anxiety disorders. Patients with comorbid conditions (e.g., major depressive disorder and GAD) have a more chronic course of illness and may require more intensive treatment to achieve remission.

While there exist standard screening instruments for depression (e.g., the Patient Health Questionnaire [PHQ-9]18) and alcohol consumption (e.g., AUDIT-C19), there is no one instrument recommended to screen for common anxiety disorders. A uniform approach to screening for anxiety could facilitate, at a national level, the performance measurement, cross-facility comparison, and quality improvement efforts of the VA health system. Selection of a single instrument should consider evidence on performance characteristics, ease of use, and ability to monitor treatment response.16,20-22 Instruments easiest to use in busy primary care settings will be in a self-report format and will not require specialized equipment or trained personnel, making them more feasible to implement. To inform decisionmaking regarding a standard screening instrument for anxiety disorders, we conducted a systematic review of the literature to evaluate the performance of self-report instruments used to diagnose GAD and PD in primary care settings.