# EXCLUDED STUDIES

All studies listed below were reviewed in their full-text version and excluded for the reason indicated. An alphabetical reference list follows the table.

Reference | Population not of interest | Setting not PC, clinic, or ER | No self-reported index test at screening | Reference standard not acceptable | No instrument characteristics data | Design not prospective | Reference standard not applied correctly | Publication not English | Screening tool not English/Spanish
Andersson, 2004 (422) | | X
Andjreu, 2008 (1551) | X
Andreescu, 2008 (124) | | | | | | X
Apfeldorf, 1994 (1690) | X
Argyropoulos, 2007 (247) | | X
Austin, 2006 (321) | | X
Baughman, 1994 (2675) | | | X
Beck, 1996 (801) | | X
Behar, 2003 (505) | | X
Berrocal, 2006 (316) | | X
Berrocal, 2006 (362) | | X
Bieling, 1998 (721) | | X
Bobes, 2006 (315) | | | | | | | | X
Bucholz, 1991 (2532) | X
Bystritsky, 1996 (810) | | X
Clum, 1990 (3010) | X
Connor, 2001 (2399) | X
Dammen, 1999 (674) | | | | | | | | X
Eack, 2006 (1478) | | X
Eack, 2008 (149) | | X
Epstein, 2001 (2417) | | X
Farvolden, 2003 (486) | | X
Fleet, 1997 (759) | | | | | | | | X
Gladstone, 2005 (345) | X
Gloster, 2008 (174) | X
Jackson, 2007 (243) | | | | | X
Kobak, 1997 (751) | X
Kuijpers, 2003 (497) | | | | | | | X
Lowe, 2003 (477) | | | | | | | | | X
Lykouras, 1996 (2256) | | X
McQuaid, 2000 (633) | | | | | | | X
Means-Christensen 2005 (343) | | | | X
Means-Christensen, 2006 (319) | X
Meyer, 1990 (946) | | X
Mori, 2003 (3846) | | | | X
Morlock, 2008 (190) | X
Mowry, 1990 (2735) | | X
Mussell, 2008 (150) | X
Newman, 2006 (310) | | X
Novy, 2001 (587) | X
Olssøn, 2005 (1625) | | | | X
Parker, 1997 (747) | X
Parkerson, 1997 (767) | | | | X
Robinson, 2010 (1021) | | X
Rollman, 2005 (371) | | | | | | | X
Sandin, 1996 (800) | X
Senior, 2007 (3868) | X
Stein, 1999 (2268) | | | | | | | X
Svanborg, 1994 (872) | X
Vujanovic, 2007 (227) | | | | X
Webb, 2008 (114) | X
Weissman, 1998 (735) | | | X
Wetherell, 2007 (271) | | X
Yingling, 1993 (886) | | | | | X

## LIST OF EXCLUDED STUDIES

Andersson G, Carlbring P, Kaldo V, et al. Screening of psychiatric disorders via the Internet. A pilot study with tinnitus patients. Nord J Psychiatry. 2004;58(4):287-91. [pmid: 15370777].
Andjreu Y, Galdón MJ, Dura E, et al. Psychometric properties of the Brief Symptoms Inventory-18 (BSI-18) in a Spanish sample of outpatients with psychiatric disorders. Psicothema. 2008;20(4):844-850. [pmid: 18940093].
Andreescu C, Belnap BH, Rollman BL, et al. Generalized anxiety disorder severity scale validation in older adults. Am J Geriatr Psychiatry. 2008;16(10):813-8. [pmid: 18827227].
Apfeldorf WJ, Shear MK, Leon AC, et al. A brief screen for panic disorder. Journal of Anxiety Disorders. 1994;8(1):71-78.
Argyropoulos SV, Ploubidis GB, Wright TS, et al. Development and validation of the Generalized Anxiety Disorder Inventory (GADI). J Psychopharmacol. 2007;21(2):145-52. [pmid: 17329293].
Austin DW, Richards JC, Klein B. Modification of the Body Sensations Interpretation Questionnaire (BSIQ-M): validity and reliability. Journal of Anxiety Disorders. 2006;20(2):237-51. [pmid: 16464707].
Baughman OL. Rapid diagnosis and treatment of anxiety and depression in primary care: The somatizing patient. The Journal of Family Practice. 1994;39(4):373-378. [pmid: 7931117].
Beck JG, Stanley MA, Zebb BJ. Characteristics of generalized anxiety disorder in older adults: a descriptive study. Behav Res Ther. 1996;34(3):225-34. [pmid: 8881092].
Behar E, Alcaine O, Zuellig AR, et al. Screening for generalized anxiety disorder using the Penn State Worry Questionnaire: a receiver operating characteristic analysis. J Behav Ther Exp Psychiatry. 2003;34(1):25-43. [pmid: 12763391].
Berrocal C, Ruiz Moreno M, Merchan P, et al. The Mood Spectrum Self-Report: validation and adaptation into Spanish. Depress Anxiety. 2006;23(4):220-35. [pmid: 16550540].
Berrocal C, Ruiz Moreno MA, Gil Villa M, et al. Multidimensional assessment of the Panic-Agoraphobic Spectrum: reliability and validity of the Spanish version of the PAS-SR. Journal of Anxiety Disorders. 2006;20(5):562-79. [pmid: 16122902].
Bieling PJ, Antony MM, Swinson RP. The State-Trait Anxiety Inventory, Trait version: structure and content re-examined. Behav Res Ther. 1998;36(7-8):777-88. [pmid: 9682533].
Bobes J, Garcia-Calvo C, Prieto R, et al. Psychometric properties of the Spanish version of the screening scale for DSM-IV Generalized Anxiety Disorder of Carroll and Davidson. Actas Esp Psiquiatr. 2006;34(2):83-93. [pmid: 16552636].
Bucholz KK, Robins LN, Shayka JJ, et al. Performance of two forms of a computer psychiatric screening interview: Version I of the DISSI. J Psychiatr Res. 1991;25(3):117-129. [pmid: 1941708].
Bystritsky A, Waikar SV, Vapnik T. Four-dimensional Anxiety and Depression Scale: a preliminary psychometric report. Anxiety. 1996;2(1):47-50. [pmid: 9160599].
Clum GA, Broyles S, Borden J, et al. Validity and reliability of the panic attack symptoms and cognitions questionnaires. Journal of Psychopathology and Behavioral Assessment. 1990;12(3):233-245.
Connor KM, Kobak KA, Churchill LE, et al. Mini-SPIN: A brief screening assessment for generalized social anxiety disorder. Depress Anxiety. 2001;14(2):137-140. [pmid: 11668666].
Dammen T, Ekeberg O, Arnesen H, et al. The detection of panic disorder in chest pain patients. Gen Hosp Psychiatry. 1999;21(5):323-32. [pmid: 10572773].
Eack SM, Greeno CG, Lee BJ. Limitations of the Patient Health Questionnaire in Identifying Anxiety and Depression in Community Mental Health: Many Cases are Undetected. Research on Social Work Practice. 2006;16(6):625-631.
Eack SM, Singer JB, Greeno CG. Screening for anxiety and depression in community mental health: the beck anxiety and depression inventories. Community Ment Health J. 2008;44(6):465-74. [pmid: 18516678].
Epstein JF, Barker PR, Kroutil LA. Mode effects in self-reported mental health data. Public Opin Q. 2001;65(4):529-549.
Farvolden P, McBride C, Bagby RM, et al. A Web-based screening instrument for depression and anxiety disorders in primary care. J Med Internet Res. 2003;5(3):e23. [pmid: 14517114].
Fleet RP, Dupuis G, Marchand A, et al. Detecting panic disorder in emergency department chest pain patients: a validated model to improve recognition. Ann Behav Med. 1997;19(2):124-31. [pmid: 9603687].
Gladstone GL, Parker GB, Mitchell PB, et al. A Brief Measure of Worry Severity (BMWS): personality and clinical correlates of severe worriers. Journal of Anxiety Disorders. 2005;19(8):877-92. [pmid: 16243636].
Gloster AT, Rhoades HM, Novy D, et al. Psychometric properties of the Depression Anxiety and Stress Scale-21 in older primary care patients. J Affect Disord. 2008;110(3):248-59. [pmid: 18304648].
Jackson JL, Passamonti M, Kroenke K. Outcome and impact of mental disorders in primary care at 5 years. Psychosom Med. 2007;69(3):270-6. [pmid: 17401055].
Kobak KA, Taylor LH, Dottl SL, et al. Computerized screening for psychiatric disorders in an outpatient community mental health clinic. Psychiatr Serv. 1997;48(8):1048-57. [pmid: 9255838].
Kuijpers PM, Denollet J, Lousberg R, et al. Validity of the hospital anxiety and depression scale for use with patients with noncardiac chest pain. Psychosomatics. 2003;44(4):329-35. [pmid: 12832599].
Lowe B, Grafe K, Zipfel S, et al. Detecting panic disorder in medical and psychosomatic outpatients: comparative validation of the Hospital Anxiety and Depression Scale, the Patient Health Questionnaire, a screening question, and physicians' diagnosis. J Psychosom Res. 2003;55(6):515-9. [pmid: 14642981].
Lykouras L, Adrachta D, Kalfakis N, et al. GHQ-28 as an aid to detect mental disorders in neurological inpatients. Acta Psychiatr Scand. 1996;93(3):212-216. [pmid: 8739669].
McQuaid JR, Stein MB, McCahill M, et al. Use of brief psychiatric screening measures in a primary care sample. Depress Anxiety. 2000;12(1):21-9. [pmid: 10999242].
Means-Christensen AJ, Arnau RC, Tonidandel AM, et al. An efficient method of identifying major depression and panic disorder in primary care. J Behav Med. 2005;28(6):565-72. [pmid: 16249822].
Means-Christensen AJ, Sherbourne CD, Roy-Byrne PP, et al. Using five questions to screen for five common mental disorders in primary care: diagnostic accuracy of the Anxiety and Depression Detector. Gen Hosp Psychiatry. 2006;28(2):108-18. [pmid: 16516060].
Meyer TJ, Miller ML, Metzger RL, et al. Development and validation of the Penn State Worry Questionnaire. Behav Res Ther. 1990;28(6):487-95. [pmid: 2076086].
Mori DL, Lambert JF, Niles BL, et al. The BAI–PC as a Screen for Anxiety, Depression, and PTSD in Primary Care. Journal of Clinical Psychology in Medical Settings. 2003;10(3):187-192.
Morlock RJ, Williams VS, Cappelleri JC, et al. Development and evaluation of the Daily Assessment of Symptoms - Anxiety (DAS-A) scale to evaluate onset of symptom relief in patients with generalized anxiety disorder. J Psychiatr Res. 2008;42(12):1024-36. [pmid: 18061206].
Mowry BJ, Burvill PW. Screening the elderly in the community for psychiatric disorder. Aust N Z J Psychiatry. 1990;24(2):203-206. [pmid: 2396964].
Mussell M, Kroenke K, Spitzer RL, et al. Gastrointestinal symptoms in primary care: prevalence and association with depression and anxiety. J Psychosom Res. 2008;64(6):605-12. [pmid: 18501261].
Newman MG, Holmes M, Zuellig AR, et al. The reliability and validity of the panic disorder self-report: a new diagnostic screening measure of panic disorder. Psychol Assess. 2006;18(1):49-61. [pmid: 16594812].
Novy DM, Stanley MA, Averill P, et al. Psychometric comparability of English- and Spanish-language measures of anxiety and related affective symptoms. Psychol Assess. 2001;13(3):347-55. [pmid: 11556271].
Olssøn I, Mykletun A, Dahl AA. The hospital anxiety and depression rating scale: A cross-sectional study of psychometrics and case finding abilities in general practice. BMC Psychiatry. 2005;5.
Parker G, Roussos J, Hadzi-Pavlovic D, et al. The development of a refined measure of dysfunctional parenting and assessment of its relevance in patients with affective disorders. Psychol Med. 1997;27(5):1193-203. [pmid: 9300523].
Parkerson GR Jr, Broadhead WE. Screening for anxiety and depression in primary care with the Duke Anxiety-Depression Scale. Fam Med. 1997;29(3):177-81. [pmid: 9085098].
Robinson CM, Klenck SC, Norton PJ. Psychometric properties of the Generalized Anxiety Disorder Questionnaire for DSM-IV among four racial groups. Cognitive Behaviour Therapy. 2010;39(4):251-261. [pmid: 20830629].
Rollman BL, Belnap BH, Mazumdar S, et al. Symptomatic severity of PRIME-MD diagnosed episodes of panic and generalized anxiety disorder in primary care. J Gen Intern Med. 2005;20(7):623-8. [pmid: 16050857].
Senior AC, Kunik ME, Rhoades HM, et al. Utility of telephone assessments in an older adult population. Psychol Aging. 2007;22(2):392-7. [pmid: 17563195].
Sandin B, Chorot P, McNally RJ. Validation of the Spanish version of the Anxiety Sensitivity Index in a clinical sample. Behav Res Ther. 1996;34(3):283-90. [pmid: 8881099].
Stein MB, Jang KL, Livesley WJ. Heritability of anxiety sensitivity: A twin study. The American Journal of Psychiatry. 1999;156(2):246-251. [pmid: 9989561].
Svanborg P, Asberg M. A new self-rating scale for depression and anxiety states based on the Comprehensive Psychopathological Rating Scale. Acta Psychiatr Scand. 1994;89(1):21-8. [pmid: 8140903].
Vujanovic AA, Arrindell WA, Bernstein A, et al. Sixteen-item Anxiety Sensitivity Index: confirmatory factor analytic evidence, internal consistency, and construct validity in a young adult sample from the Netherlands. Assessment. 2007;14(2):129-43. [pmid: 17504886].
Webb SA, Diefenbach G, Wagener P, et al. Comparison of self-report measures for identifying late-life generalized anxiety in primary care. J Geriatr Psychiatry Neurol. 2008;21(4):223-31. [pmid: 19017779].
Weissman MM, Broadhead WE, Olfson M, et al. A diagnostic aid for detecting (DSM-IV) mental disorders in primary care. Gen Hosp Psychiatry. 1998;20(1):1-11. [pmid: 9506249].
Wetherell JL, Birchler GD, Ramsdell J, et al. Screening for generalized anxiety disorder in geriatric primary care patients. Int J Geriatr Psychiatry. 2007;22(2):115-23. [pmid: 17096461].
Yingling KW, Wulsin LR, Arnold LM, et al. Estimated prevalences of panic disorder and depression among consecutive patients seen in an emergency department with acute chest pain. J Gen Intern Med. 1993;8(5):231-5. [pmid: 8505680].