# STUDY SELECTION FORM

## INCLUSION CRITERIA

- Sample population is adults age ≥18 years presenting with a somatic symptom or presenting to a medical clinic for a scheduled appointment.
- Setting is primary care (general internal medicine, family medicine, geriatrics) or general medical (emergency department, women's health clinic).
- Intervention is a self-report instrument (index test) designed to screen for or facilitate diagnosis of GAD, PD, or anxiety disorders. The instrument must be feasible in a clinical setting without requiring special equipment and may be performed by a nonexpert.
- Reference standard diagnosis of GAD or PD is made using acceptable criteria (e.g., DSM-III or later, ICD-9 or later) and administered by a trained clinician.
- Study reports a measure of reliability or sensitivity/specificity or the data to calculate at least one of these performance characteristics.
- Study design is prospective comparison of an anxiety questionnaire to a reference standard; reference standard must be applied to all subjects or to a randomly selected subsample that allows correction for verification bias.
- Study must be published in a peer-reviewed publication.

## EXCLUSION CRITERIA

- Study is a non-English language publication. English language articles that address Spanish version of instruments will be included.
- Study is conducted outside of North America, Western Europe, New Zealand or Australia.
- Study populations are patients with current mental illness (e.g., substance abuse disorder), and screening is for comorbid anxiety disorder.
- Anxiety measure and reference standard are performed by the same individual.