# SEARCH STRATEGY

Step | Category | Terms | Result^a^
1 | Disorders | (generalized AND anxiety AND disorder[tiab]) OR panic disorder[tiab] OR “generalized anxiety disorder” OR panic disorder[mesh] OR panic[title/abstract] | 12293
2 | Measurement instruments
| GAD or PD | “gad7”[tiab] OR “generalized anxiety disorder 7”[tiab] OR “gad-7”[tiab] OR “beck anxiety”[tiab] OR “geriatric anxiety inventory”[tiab] OR “short anxiety screening test”[tiab] OR “hospital anxiety and depression scale”[tiab] OR PHQ[tiab] OR “patient health questionnaire”[tiab] OR “zung anxiety scale”[tiab] OR “penn state worry questionnaire”[tiab] OR “multicenter collaborative panic disorder severity scale” | 3801
| | OR
| Broad terms for instruments | “Psychiatric Status Rating Scales”[Mesh] OR questionnaires[MeSH Terms] OR questionnaires[tiab] OR questionnaire[tiab] OR tools[tiab] OR tool[tiab] OR scale[tiab] OR scales[tiab] OR inventory[tiab] OR screening[tiab] | 1,094,242
3 | Instrument characteristics | medical history taking[mh] OR reproducibility of results[mh] OR observer variation[mh] OR sensitivity[tiab] OR specificity[tiab] OR “sensitivity and specificity”[mh] OR likelihood [tiab] OR accura*[tiab] | 1,249,615
4 | Combine results and apply limits | #1 AND #2 AND #3 English and Human and Adult | 850

a Numbers reflect the result of the PubMed search only.