# SUMMARY AND DISCUSSION

## SUMMARY OF THE EVIDENCE

In this systematic review, we examined the effectiveness, harms, and costs of intravitreal anti-VEGF treatment for retinal or choroidal neovascularization and/or macular edema. Key results are summarized in Table 6. Overall, we found no evidence of a clinically meaningful difference in visual acuity gains between the drugs for the treatment of AMD, DME, or BRVO/CRVO, although one DME trial suggests that there may be an advantage associated with aflibercept in patients with lower baseline BCVA. Most trials found no differences between drugs in rates of ocular or systemic adverse events. Because of the comparative effectiveness and harms but marked differences in price between the drugs, compounded bevacizumab was found to be the most cost-effective agent.

Table 6 Summary of the Evidence on Anti-VEGF Agents for the Treatment of Retinal/Choroidal Neovascularization and/or Macular Edema

Outcome | N studies (N=total patients randomized) | Summary of findings^a^ | Combined summary estimate | Strength of Evidence^b^ | Comments
Choroidal Neovascularization Secondary to Age-Related Macular Degeneration (AMD)
Aflibercept vs Bevacizumab
| None | --- | --- | No evidence
Aflibercept vs Ranibizumab
Mean change in BCVA | 2 RCTs (N=2457)^c^ | Mixed findings. Neither study reported a clinically meaningful difference between drugs, and pooled results show no statistically significant difference between drugs; however, despite identical designs, the 2 trials had conflicting results (one showing benefit in favor of aflibercept and the other in favor of ranibizumab), resulting in very high statistical heterogeneity.^d^ | | Insufficient | Conflicting results from 2 large trials.
% patients gaining ≥15 letters | 2 RCTs (N=2457)^c^ | No difference. Neither study reported a statistically significant difference between drugs, but one of the trials trended toward significance in favor of aflibercept and the other in favor of ranibizumab, resulting in high statistical heterogeneity.^e^ | 12 months: no difference | Low
Ocular adverse events | 2 RCTs (N=2457)^c^ | Low rates of serious ocular adverse events (2.3% at 12 months, 3.8% at 22 months) and likely no difference between drugs. By 22 months, endophthalmitis occurred in 0.8% of monthly ranibizumab groups and 0.7% of monthly aflibercept 2.0 mg groups. Intraocular pressure elevation was the most common event, reported in up to 7.2% of participants. | --- | Moderate | Statistical comparison between drugs NR.
Systemic adverse events | 2 RCTs (N=2457)^c^ | Arterial thrombotic events^f^ potentially related to intravitreal anti-VEGF agents were reported in both groups: 3.2% of monthly ranibizumab groups and 2.4% of monthly aflibercept 2.0 mg groups by 22 months. There was no evidence of a dose-response relationship for aflibercept (highest rate of exposure generally had lowest rate of events). | --- | Low | Statistical comparison between drugs NR.
Costs | 2 RCTs (N=2457)^c^ | No direct cost data was reported. Combined results from 2 trials show slightly less frequent dosing required for aflibercept compared to ranibizumab (4.1 vs 4.7 injections during the 10-month PRN portion of trial; P<.001). Based on current drug prices, this likely represents a small benefit for aflibercept during the PRN phase of the trial (∼$7600 vs $9500). | --- | Low
Bevacizumab vs Ranibizumab
Mean change in BCVA | 9 RCTs (N=3630) | No short-term or long-term significant difference between drugs. | 12 months (7 trials): Pooled ES -0.218 (-1.431 to 0.995); I^2^=5.9% 18-24 months (3 trials): Pooled ES -0.126 (-1.033 to 0.781); I^2^=0% | High | Large number of trials with fairly consistent results and precise estimate.
% patients gaining ≥15 letters | 7 RCTs (N=3455) | No short-term or long-term significant difference between drugs. | 12 months: RR 0.930 (0.804 to 1.075); I^2^=4.0% 18-24 months (4 trials): RR 0.835 (0.630 to 1.107); I^2^=44.5% | Moderate | Large number of trials but the long-term estimate is imprecise and encompasses both no difference and a substantial benefit in favor of ranibizumab.
Ocular adverse events | 6 RCTs (N=3427) | Low rates of serious ocular adverse events and there were no significant differences reported between drugs. Endophthalmitis typically occurred in <1% of patients in each treatment group (except in the CATT trial which reported 1.4% in one treatment arm at 12 months). Other specific serious ocular adverse events were also very rare (typically <1% of patients per arm). | --- | Moderate | Reporting of ocular adverse events varied between trials, and very few reported statistical differences between groups.
Systemic adverse events | 6 RCTs (N=3427) | Similar rates of serious systemic adverse events between drugs were reported in 5 of the 6 trials. Arterial thrombotic events^f^ occurred in up to 5% of each arm, and no significant differences were found between drugs in 4 of 5 trials at 12 months; the one trial finding a difference between drugs at 12 months found no difference by 24 months. No differences were found between drugs in rates of death. Bevacizumab was associated with higher rates of gastrointestinal events in 2 of 6 trials. | --- | Moderate
Cost | 1 RCT (N=1208) | Per-dose and two-year injection costs of compounded bevacizumab^g^ were substantially lower than ranibizumab in one trial (PRN groups $705 vs $25,200 per patient; monthly groups $1,170 vs $44,800 per patient). Based on injection frequencies reported in other trials, differential costs were likely similar. No evidence of incremental cost-effectiveness benefit for the more expensive ranibizumab. | --- | Moderate
Diabetic Macular Edema (DME)
Aflibercept vs Bevacizumab
Mean change in BCVA | 1 RCT (N=442) | Some benefit in favor of aflibercept. Results of one trial showed a benefit for aflibercept over bevacizumab at 12 and 24 months, but the difference was likely not clinically meaningful^a^ (12-month mean difference 3.5 letters [95% CI, 1.4 to 5.7], P<.001; 24-month mean difference 2.7 letters [95% CI, 0.3 to 4.2], P=.02). However, the benefit of aflibercept over bevacizumab was clinically meaningful at 12 months in a subgroup analysis of patients with lower baseline BCVA (mean difference 6.5 letters [95% CI, 2.9 to 10.1]; P<001). The difference was significant but smaller in this subgroup by 24 months (mean difference 4.7 letters [95% CI, 0.5 to 8.8]; P=.02). | --- | Low | One trial showed a small difference between drugs that was likely not clinically meaningful; however, the difference was clinically meaningful in a subgroup of patients with lower baseline BCVA.
% patients gaining ≥15 letters | 1 RCT (N=442) | Small benefit for aflibercept in the short-term but not long-term. Results of one trial showed a benefit with aflibercept over bevacizumab at 12 months (P=.028), but no difference was found by 24 months (P=.70). Similar results were found in a subgroup analysis of patients with lower baseline BCVA (P<.001 at 12 months; P=.74 at 24 months). | --- | Low | One trial showed a difference between drugs at 12 months that was not present by 24 months.
Ocular adverse events | 1 RCT (N=442) | No difference. Rates of most ocular adverse events within 24 months were very low (including endophthalmitis, <0.5% of both arms), with the exception of vitreous hemorrhage (7% of patients) and elevated intraocular pressure (15% of patients), but no differences were found between groups. | --- | Low
Systemic adverse events | 1 RCT (N=442) | No difference. Rates of arterial thrombotic events^f^ were similar between groups at 24 months (5.4% vs 7.8%, P=.34). Rates of other events were high, likely due to poor health at baseline, but no differences were found between groups. | --- | Low
Cost | 1 RCT (N=442) | Total one-year treatment costs (including injections, rescue laser photocoagulation, and adverse events) were substantially lower for compounded bevacizumab^g^ than for aflibercept ($4,100 vs $26,100 per patient). Validated 10-year modeling projections found no incremental cost-effectiveness benefit for the more expensive aflibercept (very high cost for modest quality of life gains), including for the subgroup with lower baseline BCVA. | --- | Moderate
Aflibercept vs Ranibizumab
Mean change in BCVA | 1 RCT (N=442) | Small benefit with aflibercept in the short-term but not long-term. Results of one trial showed a benefit for aflibercept over ranibizumab at 12 months, but the difference was likely not clinically meaningful (mean difference 2.1 letters [95% CI, 0.1 to 4.2], P=.034). This benefit was more pronounced in a subgroup of patients with lower baseline BCVA (mean difference 4.7 letters [95% CI, 1.4 to 8.0], P=.003). No significant differences were found between the drugs at 24 months in either the full analysis or subgroup analyses by baseline BCVA. | --- | Low | One trial showed a small difference between the drugs at 12 months that was likely not clinically meaningful; the benefit was more significant in a subgroup with lower baseline BCVA, but no differences were found in either group by 24 months.
% patients gaining ≥15 letters | 1 RCT (N=442) | No significant difference was found between drugs at 12 (P=.068) or 24 months (P=.70). However, subgroup analyses of patients with lower baseline BCVA showed a greater relative benefit with aflibercept at 12 months (P=.008), but not by 24 months (P=.75). | --- | Low
Ocular adverse events | 1 RCT (N=442) | No difference. Rates of most ocular adverse events within 24 months were very low (no occurrences of endophthalmitis), with the exception of vitreous hemorrhage (6% of patients) and elevated intraocular pressure (17% of patients), but no differences were found between groups. | --- | Low
Systemic adverse events | 1 RCT (N=442) | Higher rates of arterial thrombotic events^f^ were reported in the intravitreal ranibizumab arm (5.4% vs 11.9% at 24 months, P=.047). Rates of other events were high, likely due to poor health at baseline, but no differences were found between groups. | --- | Low
Cost | 1 RCT (N=442) | Total one-year treatment costs (including injections, rescue laser photocoagulation, and adverse events) were lower for ranibizumab than aflibercept ($18,600 vs $26,100 per patient). Validated 10-year modeling projections found no incremental cost-effectiveness benefit for the more expensive aflibercept,^h^ including for the subgroup with lower baseline BCVA. | --- | Moderate
Bevacizumab vs Ranibizumab
Mean change in BCVA | 3 RCTs (N=584) | No difference. Pooled results of 3 trials showed no difference between drugs at 12 months, and 24-month results of one trial also found no difference (mean difference 2.0 letters [95% CI, -0.4 to 4.4]). | 12 months: Pooled ES -1.190 (-2.889 to 0.509); I^2^=0% | Moderate | Fairly wide confidence interval in pooled results of 3 trials.
% patients gaining ≥15 letters | 2 RCTs (N=484) | No difference. Pooled results of 2 trials showed no difference between drugs at 12 months, and 24-month results of one trial also found no difference (P=.70). | 12 months: RR 0.871 (0.670 to 1.133); I^2^=0% | Moderate
Ocular adverse events | 3 RCTs (N=584) | Mixed findings. One large trial reported very low rates of endophthalmitis (<0.5% in both arms), while a smaller trial reported 7% affected in one treatment group (statistical difference between drugs NR). Another study reported an overall rate of 3% but results were not reported by group. No differences reported between groups for other ocular adverse events and rates were generally low, except for vitreous hemorrhage (6% of patients) and elevated intraocular pressure (14% of patients) in one large trial. | --- | Moderate
Systemic adverse events | 3 RCTs (N=584) | No difference. Rates of arterial thrombotic events^f^ were similar between groups at 24 months (7.8% vs 11.9%, P=.20) in one large trial. Rates of other events were high, likely due to poor health at baseline, but no differences were found between groups. | --- | Low | Data primarily from 1 large trial; 2 smaller trials had no events or insufficient reporting of events by group.
Cost | 1 RCT (N=336) | Total one-year treatment costs (including injections, rescue laser photocoagulation, and adverse events) were substantially lower for compounded bevacizumab^g^ than for ranibizumab ($4,100 vs $26,100 per patient). Validated 10-year modeling projections found no incremental cost-effectiveness benefit for the more expensive ranibizumab. | --- | Moderate
Macular Edema due to Central Retinal Vein Occlusion (CRVO) or Branch Retinal Vein Occlusion (BRVO)
Aflibercept vs Bevacizumab
| None | --- | --- | No evidence
Aflibercept vs Ranibizumab
| None | --- | --- | No evidence
Bevacizumab vs Ranibizumab
Mean change in BCVA | 2 RCTs (N=177) | No difference. Pooled results of 2 relatively small trials found no difference between drugs at 6 months. | 6 months: Pooled ES -1.204 (-5.714 to 3.306); I^2^=0% | Insufficient | Two small short-term trials provide an imprecise estimate.
% patients gaining ≥15 letters | 2 RCTs (N=177) | No difference. Pooled results of 2 relatively small trials found no difference between drugs at 6 months. | 12 months: RR 0.992 (0.805 to 1.223); I^2^=0% | Insufficient | Two small short-term trials.
Ocular adverse events | 2 RCTs (N=177) | Two small trials provide insufficient data. Serious ocular adverse events were relatively rare in 2 small trials, and there were no instances of endophthalmitis. | --- | Insufficient | Two small short-term trials with low event rates.
Systemic adverse events | 2 RCTs (N=177) | Two small trials provide insufficient data. | --- | Insufficient | Two small short-term trials with low event rates.
Cost | None | --- | --- | No evidence

Abbreviations: AMD = age-related macular degeneration; BCVA = best-corrected visual acuity; BRVO = branch retinal vein occlusion; CATT = Comparison of AMD Treatments Trials; CI = confidence interval; CRVO = central retinal vein occlusion; DME = diabetic macular edema; ES = effect size; N = number; NR = not reported; PRN = pro re nata (“as needed”); RCT = randomized controlled trial; RR = relative risk; VEGF = vascular endothelial growth factor

a A clinically meaningful difference in mean change in BCVA was defined as a difference of ≥ 5 ETDRS letters between drugs.

b The overall quality of evidence for each outcome is based on the consistency, coherence, and applicability of the body of evidence, as well as the internal validity of individual studies. The strength of evidence is classified as follows:

- High = Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient = Any estimate of effect is very uncertain.

c N=1226 for the 2 main groups of interest, the recommended dose of each drug administered monthly (2.0 mg aflibercept monthly vs 0.5 mg ranibizumab monthly).

d Pooled results showed a nonsignificant difference in mean BCVA change of 0.592 letters (95% CI, -4.406 to 5.590; P=.817), but should be interpreted with caution due to significant statistical heterogeneity (I^2^=90.4%).

e Pooled results showed a nonsignificant RR of 1.045 (95% CI, 0.767 to 1.425; P=.780), but should be interpreted with caution due to significant statistical heterogeneity (I^2^=72.6%).

f Defined by the Anti-Platelet Trialists' Collaboration as vascular death, nonfatal myocardial infarction, or nonfatal stroke.

g Compounded bevacizumab is not currently available within the VHA.

h Cost-effectiveness calculations for this study were based on the ranibizumab dose recommended for DME patients (0.3 mg); the cost of ranibizumab at the dose recommended for AMD and BRVO/CRVO (0.5 mg) is more expensive than aflibercept.

In patients with AMD and DME, we found moderate- to high-strength evidence that there was no difference in clinically important visual outcomes between bevacizumab and ranibizumab. We found insufficient to low-strength evidence of either no difference or a small visual acuity benefit for aflibercept over both bevacizumab and ranibizumab, particularly in patients with poorer visual acuity at baseline. The very limited evidence found for BRVO and CRVO populations is insufficient from which to draw conclusions about the comparative effectiveness of bevacizumab and ranibizumab (no evidence for the other drug comparisons).

Ocular adverse events generally occurred very rarely in the included trials and we found low- to moderate-strength evidence of no difference between the anti-VEGF agents. Rates of systemic adverse events were also similar between drugs in most trials (low- to moderate-strength evidence), although one trial reported higher rates of arterial thrombotic events with intravitreal ranibizumab compared to intravitreal aflibercept in patients with DME (low-strength evidence). There was insufficient evidence about adverse events for BRVO/CRVO patients; however, because most of the adverse events associated with these treatments are usually related to the intraocular injection rather than the clinical condition, it is likely that the comparative rates of adverse events in patients with RVO are similar to those found in the other populations.

Regarding comparative costs, one DME trial and one AMD trial provided moderate-strength evidence that treatment with both ranibizumab and aflibercept is considerably more expensive than compounded bevacizumab and provide no incremental cost-effectiveness benefits. Ten-year modeling, sensitivity analyses, and subgroup analyses of patients with lower baseline BCVA confirm the substantial cost-effectiveness of compounded bevacizumab compared to the other agents. In patients with DME, ranibizumab was more cost-effective than the more expensive aflibercept (moderate-strength evidence). No studies assessed the costs of bevacizumab when it was not compounded (the current method employed by the VHA).

Our findings on the comparative effectiveness of anti-VEGF agents are consistent with other recent population-specific systematic reviews which found no significant differences between drugs. Two recent comparative effectiveness reviews of AMD trials found no differences in visual acuity improvements between aflibercept and ranibizumab,^6^ or between bevacizumab and ranibizumab (mean difference in BCVA change -1.15 letters [95% CI, -2.82 to 0.51] at 2 years; likelihood of gaining 15 or more letters RR 0.90 [95% CI, 0.73 to 1.11] at one year).^9^ The most recent systematic review of DME trials was published before results were available for DRCR.net Protocol T, by far the largest trial completed in this population; however, the review and a network meta-analysis using indirect data from 5 trials also found no differences in visual acuity between bevacizumab and ranibizumab.^8,50^ No comparative systematic reviews were found for RVO, but a network meta-analysis found no differences between aflibercept, bevacizumab, and ranibizumab.^51^

In the individual trials included in our systematic review, relatively large standard deviations in mean change in BCVA (≥ 10 ETDRS letters/2 lines in all studies reporting this outcome) indicate that there was substantial variability in patients' responses to the anti-VEGF agents, with some gaining significantly more letters than others. Several studies have examined the reason for this variation and have found several factors that predict response to anti-VEGF treatment, such as younger age, prompt treatment initiation, and smaller area of neovascularization.^52,53^ Genetic factors also appear to moderate response to anti-VEGF treatment, as studies have found several single nucleotide polymorphisms associated with change in visual acuity.^52,54-58^ A combination of these and other factors likely explain why some patients respond very positively to anti-VEGF treatment, while others continue to lose visual acuity despite frequent injections.^57^ While individual patients may respond differently to each anti-VEGF agent, it is unclear whether there are specific subgroups of patients who can be proactively identified as more favorably responding to one anti-VEGF agent versus another.

Another important factor involved in treatment response is visual acuity at baseline; studies have shown that higher baseline BCVA is associated with smaller BCVA gains during treatment,^52,53,59,60^ including subgroup analyses of the DRCR.net Protocol T trial included in our review.^46,47^ This phenomenon suggests that there may be a ceiling effect of anti-VEGF treatment, wherein visual acuity improvement plateaus after a ceiling BCVA is achieved (such as ≥ 70 ETDRS letters, as proposed by Sivaprasad 2014).^59^ Thus, even though patients with good baseline BCVA are more likely to report good BCVA at follow-up, these patients will be less likely to show substantial improvement during the trial period—the primary outcome in most studies. The majority of the trials discussed in this review had inclusion criteria that allowed the enrollment of patients with baseline BCVA well above this threshold, which may help explain some of the variance in treatment response.

It is important to note that due to the rare nature of most serious systemic adverse events, the majority of studies included in this review were not powered to detect differences between groups for harms. However, our findings are consistent with a recent systematic review of 9 published and unpublished AMD trials which found that intravitreal bevacizumab and ranibizumab had similar rates of serious systemic adverse events (24% bevacizumab vs 22.2% ranibizumab; RR 1.08 [95% CI, 0.90 to 1.31]).^61^ A sensitivity analysis excluding unpublished studies increased this relative risk to 1.21 (95% CI, 1.06 to 1.37), indicating possible publication bias that favors studies showing a difference between the drugs; in fact, this is very similar to the risk reported by another recent systematic review that did not include several recent studies (RR 1.27 [95% CI, 1.06 to 1.52]).^9^ The review also found no differences in rates of death (3.7% bevacizumab vs 3.4% ranibizumab; RR 1.10 [95% CI, 0.78 to 1.57]) or arterial thrombotic events (3.2% bevacizumab vs 3.5% ranibizumab; RR 0.92 [95% CI, 0.62 to 1.37]).^61^ However, gastrointestinal disorders were more common in the intravitreal bevacizumab groups (2.9% bevacizumab vs 1.6% ranibizumab; RR 1.82 [95% CI, 1.04 to 3.19]), and they tended to have more systemic infections (5% bevacizumab vs 3.7% ranibizumab; RR 1.34 [95%, 0.97 to 1.86]), although the difference did not reach statistical significance. Another systematic review found no difference between bevacizumab and ranibizumab in rates of major cardiovascular events (odds ratio [OR] 0.94 [95% CI, 0.59 to 1.52]) or non-ocular hemorrhage (OR 2.56 [95% CI, 0.78 to 8.38]), but bevacizumab was associated with higher rates of venous thromboembolic events (OR 3.45 [95% CI, 1.25 to 9.54]).^62^

Since bevacizumab is often compounded (where the contents of the sterile vial in which the drug comes packaged are separated into smaller doses for use in intravitreal injections), there is the potential to introduce contaminants that can cause infections like endophthalmitis.^63^ However, the trials included in this review found no significant differences in the incidence of endophthalmitis between drugs, suggesting that proper aseptic compounding techniques can make bevacizumab as safe as the drugs packaged specifically for intravitreal injection. On the other hand, it is possible that these strictly controlled trials with very specific protocols regarding drug handling had lower incidences of endophthalmitis than is found with normal clinical practice. Furthermore, some studies also used antibacterial measures (such as topical antibiotics for several days after the injection) that may not be commonplace in routine practice. However, meta-analyses that included both clinical trials and observational studies also reported a very low incidence of endophthalmitis after anti-VEGF injection (ranging from 0.038% to 0.065%),^64^ and 3 fairly recent large retrospective studies found either no difference between drugs,^65^ or slightly lower rates after injection with bevacizumab (0.012%-0.017% vs 0.018-0.025% after ranibizumab injection and 0.031% after aflibercept).^66,67^

While very few differences were found between intravitreal anti-VEGF agents in rates of systemic adverse events in both our review and previous reviews, it is important to note that intravitreal anti-VEGF agents have been shown to pose an increased risk for some systemic harms when compared with sham injections or other treatments. This increased risk is presumably because a portion of the anti-VEGF agents injected into the eye reach the body's bloodstream and reduce systemic VEGF levels; there have also been reports that plasma anti-VEGF levels may be higher after intravitreal bevacizumab injections than the other 2 anti-VEGF drugs (likely due to its longer half-life),^68,69^ but the clinical significance of this finding is unclear given the scarcity of empiric data showing higher rates of adverse events with intravitreal bevacizumab compared to the other anti-VEGF agents. A systematic review comparing intravitreal aflibercept or ranibizumab to sham and laser treatments in patients with DME found that the intravitreal anti-VEGF agents were associated with significantly increased rates of death (OR 2.98 [95% CI, 1.44 to 6.14]), cerebrovascular accidents (OR 2.33 [95% CI, 1.04 to 5.22]), and vascular death (OR 2.51 [95% CI, 1.08 to 5.82).^70^ Another systematic review including various clinical populations found no increased risk of mortality or major cardiovascular (arterial thrombotic) events with anti-VEGF treatment, but patients treated with intravitreal ranibizumab had a slightly greater risk of non-ocular hemorrhage compared to sham/control groups (OR 1.57 [95% CI, 1.01 to 2.44]).^62^ Patients with the conditions included in this review often have an increased risk of cardiovascular events, and thus clinicians and patients at high risk need to weigh the additional risk of systemic adverse events with the improved visual acuity offered by intravitreal anti-VEGF injections.

## LIMITATIONS

There are several limitations in the body of evidence included in this review. While many of the included trials had low ROB, a number of studies had methodological limitations that should be considered, such as lack of ITT analysis, poor reporting on adverse events, and unclear or insufficient methods of randomization, allocation concealment, and blinding. In addition, the paucity of trials enrolling patients with BRVO and CRVO limited the conclusions we could make about anti-VEGF agents in these populations. Aflibercept was also studied less often than the other agents, likely due to its relatively recent FDA approval. Several trials excluded patients with cardiovascular risk factors, limiting their applicability to many patients receiving anti-VEGF treatment.

Both trials that contributed evidence on costs used compounded bevacizumab; thus, we have limited evidence about comparative costs when the commercially available bevacizumab vial is used for only one injection (approximately 10 times the cost of compounded bevacizumab). This may be even more relevant in the future, as the FDA published a draft guidance document in February 2015 stating that repackaged biologic products must be used or discarded within 4 hours; if approved, this will effectively preclude the use of compounded bevacizumab.^71,72^ Nevertheless, because the cost of the bevacizumab vial is less than per-dose costs of the other drugs and given their comparative effectiveness and harms, non-compounded bevacizumab is likely still more cost-effective than the other agents. However, in choosing amongst these drugs, clinicians may also need to consider factors such as patient preference, convenience, and distance to facility. Unlike most patients in the general population, many VHA patients must travel hundreds of miles to receive anti-VEGF injections, and thus the less frequent dosing possible with aflibercept could translate to reduced burden to the physician and patient as well as lower transportation expenses, although the cost implications of this were not specifically addressed in the studies. A large ongoing trial (estimated N=706) comparing ranibizumab PRN to bimonthly aflibercept in patients with AMD should help clarify the possible differences in dosing frequency between these drugs (NCT01958918 at ClinicalTrials.gov).

Another limitation of this systematic review was our decision to include only controlled trials for effectiveness and harms data. This may have omitted important data from observational studies, such as information about longer-term effects and rare harms. However, randomized controlled trials are considered the “gold standard” for determining the effectiveness of interventions and therefore provided the best evidence for answering these key questions. The large size and detailed adverse event reporting of many of the included trials provided strong evidence about potential harms, although it should be noted that they were not powered to detect differences between drugs in rates of these relatively rare adverse events. In addition, a recently published review by the Canadian Agency for Drugs and Technologies in Health assessed the data on the bevacizumab's safety from any study design and came to the same conclusion as our review, finding that both the body of evidence as a whole as well as the most credible evidence indicate that bevacizumab is not associated with an increased risk of either cardiovascular and ophthalmic adverse events compared to ranibizumab.^73^

Another potential limitation of our review was our decision to examine the evidence according to clinical condition, which may have limited our power to detect differences between drugs. However, while the disease entities may share certain similarities, such as VEGF as a driving force, we felt that the distinct pathophysiology for each disease precluded the appropriateness of combining the conditions. Furthermore, exploratory meta-analyses pooling data from all disease groups (AMD, DME, and BRVO/CRVO) resulted in similar findings to the disease-specific summary estimates, with no significant differences found between drugs.

## RESEARCH GAPS/FUTURE RESEARCH

While we identified several large RCTs with low ROB in patients with AMD, and one large low-ROB trial in patients with DME, there were no large, high-quality trials in patients with RVO. Fortunately, there are a few ongoing trials expected to be completed in the coming years that should help to ameliorate this evidence gap. An RCT currently being completed at the University of Amsterdam is comparing bevacizumab to ranibizumab treatment over 6 months in 296 BRVO patients (NCT01635803). Another large RCT (expected N=362), expected to be completed in March 2019, is comparing 6 months of treatment with aflibercept to bevacizumab in patients with CRVO (SCORE 2, NCT01969708). The third study included a fewer number of patients with CRVO (N=40), but will compare aflibercept and ranibizumab over 18 months (NCT02274259); results will likely be published shortly.

We also found very few studies reporting data on functional status and quality of life. While visual acuity outcomes are arguably the most important outcome when comparting intravitreal anti-VEGF agents, how the drugs affect patients' functioning and well-being is an important clinical consideration and one for which there is very little evidence. Also, as mentioned previously, our current evidence on cost outcomes are mostly limited to the cost of the drugs themselves, and thus future research should consider other costs associated with anti-VEGF treatment (eg, office visits, OCT imaging, and adverse events).

Only a few of the included studies evaluated the anti-VEGF agents for follow-up periods longer than one year, and the longest follow-up occurred after 2 years of treatment. Several retrospective studies or open-label extensions of trials have reported outcomes for up to 5 years of treatment, but they did not compare anti-VEGF agents.^74-76^ We therefore have insufficient data regarding whether there are differences in effectiveness or harms between the drugs after longer periods of use. Since repeated injections are needed to avoid deteriorating visual acuity, future RCTs or large, methodologically rigorous observational studies should compare outcomes after the long-term use of these agents.

Finally, more trials are needed to determine the effectiveness of aflibercept compared to both bevacizumab and ranibizumab. Because the DRCR.net Protocol T trial in patients with DME found important differences in effectiveness between patients with lower compared to higher baseline visual acuity, future studies should also consider stratifying change in visual acuity by baseline BCVA in order to determine whether this is finding is reproduced in other disease populations as well.

## CONCLUSIONS

This systematic review found intravitreal aflibercept, bevacizumab, and ranibizumab to have comparable effects on visual acuity and similar rates of ocular and systemic harms. Although no drug had a clear, consistent, clinically meaningful advantage over another agent, one trial of DME patients reported a small benefit for aflibercept over both bevacizumab and ranibizumab that was diminished or no longer significant after 24 months of treatment; however, the benefit of aflibercept was clinically meaningful at 12 months in a subgroup of patients with lower baseline visual acuity. Thus, more research is needed to characterize the potential benefits of aflibercept over the other agents. On the other hand, costs of treatment with compounded bevacizumab were shown to be substantially and consistently lower and thus the drug had a cost-effectiveness advantage over the other 2 agents. Potential tradeoffs for bevacizumab's cost-effectiveness include the inconvenience of slightly more frequent dosing and theoretical safety concerns related to compounding and higher blood plasma levels of the drug, although we found limited empirical data of any difference in harms between bevacizumab and the other anti-VEGF agents. Clinicians should also consider factors such as patient preference, individual treatment response, convenience, and distance to treatment facility when choosing amongst these 3 anti-VEGF agents.