# RESULTS

## LITERATURE FLOW

Results of the literature search and selection process are summarized in the literature flow diagram (Figure 1). The combined literature searches resulted in 6,330 potentially relevant citations and another 20 were identified from the bibliographies of studies and systematic reviews, for a total of 6,350 citations. After reviewing abstracts and titles according to inclusion criteria (Table 1), 127 articles were selected for full-text review. After dual review of full-text articles, 16 individual controlled trials reported in 22 publications met inclusion criteria. We received responses to our unpublished data requests from the anti-VEGF drug manufacturers Regeneron and Genentech, but there were no additional comparative trial data that met our inclusion criteria in these materials.

Figure 1 Literature Flow Chart

Abbreviations: AMD = age-related macular degeneration; BRVO = branch retinal vein occlusion; CRVO = central retinal vein occlusion; DME = diabetic macular edema; VEGF = vascular endothelial growth factor.

a 6330 references were identified through database searches (Appendix A), and an additional 20 references were identified from the bibliographies of relevant systematic reviews and primary studies

## KEY QUESTION 1 What is the comparative clinical effectiveness of anti-VEGF agents for retinal/choroidal neovascularization and/or macular edema in adults?

### Overview of Results

We identified 16 trials comparing the clinical effectiveness of anti-VEGF agents (7 with low ROB, 4 with unclear ROB, and 5 with high ROB). The majority (11 trials) examined their effectiveness for choroidal neovascularization secondary to AMD, 3 trials assessed the drugs in patients with DME, and 2 trials included patients with macular edema due to BRVO or CRVO. The majority of studies compared bevacizumab to ranibizumab, but 2 identically-designed trials compared aflibercept to ranibizumab and one study compared all 3 included anti-VEGF drugs. Trials used standard recommended doses of the drugs unless otherwise indicated (aflibercept 2.0 mg; bevacizumab 1.25 mg; ranibizumab 0.5 mg for AMD and BRVO/CRVO, and 0.3 mg for DME).

In patients with AMD, we found consistent, high-strength evidence from 9 randomized controlled trials (RCTs) that bevacizumab and ranibizumab do not differ in mean BCVA improvement at 12 or 24 months. Similarly, no difference was found between drugs in the proportion of patients gaining 15 or more ETDRS letters from baseline, but the estimate at 18 to 24 months was imprecise, leading to a moderate-strength evidence rating. Two trials comparing aflibercept to ranibizumab provide insufficient evidence regarding mean change in BCVA due to conflicting results between the trials, and low-strength evidence of no significant difference between the drugs in the proportion of patients gaining 15 or more letters. No studies compared aflibercept to bevacizumab in AMD patients.

Three trials in patients with DME provide moderate-strength evidence of no difference between bevacizumab and ranibizumab in either mean BCVA change or percentage of patients gaining 15 or more letters at 12 months, and the one trial assessing outcomes at 24 months also found no difference. One large trial provides low-strength evidence of a small benefit with aflibercept over both bevacizumab and ranibizumab in mean BCVA change in patients with DME, particularly in a subgroup of patients with lower baseline BCVA. Significant differences in the proportion of patients gaining 15 or more letters were found between aflibercept and bevacizumab at 12 but not 24 months, and no significant differences were found between aflibercept and ranibizumab for this outcome at either timepoint.

The 2 small trials in patients with BRVO or CRVO found no difference between bevacizumab and ranibizumab in mean BCVA change or proportion of patients gaining 15 or more letters, but the evidence was insufficient to draw firm conclusions due to the small number of patients and a wide confidence interval of the effect estimate.

### Trial Characteristics

Treatment arms among the trials ranged in size from 8 patients^26^ to 323 patients.^27^ The studies were conducted across various countries, including 5 conducted in the US. The majority of trials included patients with a wide range of baseline visual acuity (study means ranging from 34.2 to 68.0 ETDRS letters; mean across studies was 58 letters), from mild vision loss (75 to 90 ETDRS letters) to severe vision loss (35 to 50 letters).^28^ However, the majority of studies included mostly patients with moderate vision loss (55 to 70 letters) at baseline.

Five studies had methodological limitations resulting in high ROB ratings^26,29-32^; ROB was unclear in 4 studies,^33-36^ and low in 7 studies^27,37-47^ (Appendix B). Major limitations included insufficient or unclear methods of randomization or allocation concealment,^26,30-34,36^ insufficient blinding,^30,32,36,41,42^ and incomplete reporting of outcome data (including unclear loss to follow-up reporting, lack of intention-to-treat [ITT] analyses, and poor reporting of harms).^26,27,30-35,37,38^

### Detailed Results

#### Choroidal Neovascularization Secondary to Age-Related Macular Degeneration (AMD)

Eleven trials comparing anti-VEGF agents for AMD met inclusion criteria, including 6 studies with low ROB, 3 studies with unclear ROB, and 2 studies with high ROB. The trials most commonly compared bevacizumab to ranibizumab, but 2 studies compared ranibizumab to aflibercept. The majority of studies included patients in their late 70s and had mean baseline BCVAs between 55 and 60 ETDRS letters. Treatment schedules varied significantly between studies, although most studies used variations of pro re nata (PRN, “as needed”) dosing (either from the outset or after 3 monthly loading doses; detailed dosing schedules for each trial are reported in Appendix D). Eight of the studies enrolled at least 300 patients, with 3 including over 1000 patients (CATT, N=1208; VIEW 1, N=1217; VIEW 2, N=1240). Study details are found in Table 2 (additional study information is provided in Appendix D).

Table 2 Effectiveness of Anti-VEGF Agents for Choroidal Neovascularization Secondary to AMD

Study name; Author year; - Population; - Number randomized; - Length of follow-up; - Population characteristics: mean age, % male, mean baseline BCVA | Interventions Groups (number per group); - Treatment schedule | Main Outcomes:; - Visual acuity (reported as ETDRS chart letters unless otherwise indicated); - Quality of life (QOL) measures; - Anatomic outcomes (reported in μm unless otherwise indicated) | Notes; - ROB; - Other notes
Aflibercept vs Ranibizumab
VIEW 1 (VEGF Trap-Eye: Investigation of Efficacy and Safety in Wet AMD Trial 1); Heier 2012^43^; - Active subfoveal CNV lesions or juxtafoveal lesions with leakage affecting the fovea, secondary to AMD.; - 1217 (1210 analyzed); - 12 months (22 month results combined with VIEW 2 and reported separately); - 78 years (SD 8.0), 41.2% male, 55.1 letters (SD 13.1) | Group 1: Aflibercept 2.0 mg monthly (n=304) Group 2: Aflibercept 0.5 mg^a^ monthly (n=304) Group 3: Aflibercept 2.0 mg every other month (after 3 initial monthly doses; n=303) Group 4: Ranibizumab 0.5 mg monthly (n=306); - Schedule: Patients were seen every 4 weeks and given either active treatment or a sham injection depending on randomization group (ie, Group 3 received sham every other visit). | Aflibercept 2 mg monthly vs Aflibercept 0.5 mg^a^ monthly vs Aflibercept 2 mg bimonthly vs Ranibizumab 0.5 mg monthly Visual acuity outcomes:; - BCVA, mean change at 12 months: 10.9 (SD 13.8) vs 6.9 (SD 13.4) vs 7.9 (SD 15.0) vs 8.1 (SD 15.3); LS mean difference:; ▪ Group 1 vs Group 4: 3.15 (95% CI, 0.92 to 5.37), P=.0054; ▪ Group 2 vs Group 4: -0.80 (95% CI, -3.03 to 1.43), P=.4793; ▪ Group 3 vs Group 4: 0.26 (95% CI, -1.97 to 2.49), P=.8179; - % of participants gaining ≥15 letters at 12 months: 37.5% vs 24.9% vs 30.6% vs 30.9%; LS mean difference:; ▪ Group 1 vs Group 4: 6.58 (95% CI, -0.98 to 14.14), P=.1042; ▪ Group 2 vs Group 4: -6.00 (95% CI, -13.17 to 1.16), P=.1037; ▪ Group 3 vs Group 4: -0.36 (95% CI, -7.74 to 7.03), P=.93; - % with BCVA of 20/40 (Snellen chart) or better at 12 months: 45.7% vs 34.9% vs 37.9% vs 34.5%; P=NR; QOL outcomes:; - NEI VFQ-25 score, mean change at 12 months: 6.7 (SD 13.5) vs 4.5 (SD 11.9) vs 5.1 (SD 14.7) vs 4.9 (SD 14.0); LS mean difference:; ▪ Group 1 vs Group 4: 1.28 (95% CI, -0.73 to 3.28), P=.2090; ▪ Group 2 vs Group 4: -0.67 (95% CI, -2.69 to 1.35), P=.5128; ▪ Group 3 vs Group 4: -0.60 (95% CI, -2.61 to 1.42), P=.5579; Anatomic outcomes:; - CRT, mean change at 12 months: -116.5 (SD 98.4) vs -115.6 (SD 104.1) vs -128.5 (SD 108.5) vs -116.8 (SD 109.0); P=NR; - Cystic intraretinal edema and subretinal fluid absent on OCT (“dry retina”):^b^ 64.8% vs 56.7% vs 63.4% vs 63.6%; P=NR | - Low ROB; - Non-inferiority study.
VIEW 2 (VEGF Trap-Eye: Investigation of Efficacy and Safety in Wet AMD Trial 2); Heier 2012^43^; - Active subfoveal CNV lesions or juxtafoveal lesions with leakage affecting the fovea, secondary to AMD.; - 1240 (1202 analyzed); - 12 months (22 month results combined with VIEW 1 and reported separately); - 73.9 years (SD 8.7), 44.5% male, 52.4 letters (SD 13.9) | Group 1: Aflibercept 2.0 mg monthly (n=313) Group 2: Aflibercept 0.5 mg^a^ monthly (n=311) Group 3: Aflibercept 2.0 mg every other month (after 3 initial monthly doses; n=313) Group 4: Ranibizumab 0.5 mg monthly (n=303); - Schedule: Patients were seen every 4 weeks and given either active treatment or a sham injection depending on randomization group (ie, Group 3 received sham every other visit). | Aflibercept 2 mg monthly vs Aflibercept 0.5 mg^a^ monthly vs Aflibercept 2 mg bimonthly vs Ranibizumab 0.5 mg monthly Visual acuity outcomes:; - BCVA, mean change at 12 months: 7.6 (SD 12.6) vs 9.7 (SD 14.1) vs 8.9 (SD 14.4) vs 9.4 (SD 13.5); LS mean difference:; ▪ Group 1 vs Group 4: -1.95 (95% CI, -4.10 to 0.20), P=.076; ▪ Group 2 vs Group 4: -0.06 (95% CI, -2.24 to 2.12), P=.955; ▪ Group 3 vs Group 4: -0.90 (95% CI, -3.06 to 1.26), P=.4131; - % of participants gaining ≥15 letters at 12 months: 29.4% vs 34.8% vs 31.4% vs 34.0%; LS mean difference:; ▪ Group 1 vs Group 4: -4.57 (95% CI, -12.02 to 2.88), P=.229; ▪ Group 2 vs Group 4: 0.78 (95% CI, -6.91 to 8.46), P=.843; ▪ Group 3 vs Group 4: -2.65 (95% CI, -10.18 to 4.88), P=.490; - % with BCVA of 20/40 (Snellen chart) or better at 12 months: 32.7% vs 32.4% vs 27.5% vs 35.7%; P=NR; QOL outcomes:; - NEI VFQ-25 score, mean change at 12 months: 4.5 (SD 15.0) vs 5.1 (SD 13.7) vs 4.9 (SD 14.7) vs 6.3 (SD 14.8); LS mean difference:; ▪ Group 1 vs Group 4: -2.79 (95% CI, -4.90 to -0.68), P=.0097; ▪ Group 2 vs Group 4: -0.93 (95% CI, -3.07 to 1.20), P=.3917; ▪ Group 3 vs Group 4: -1.95 (95% CI, -4.07 to 0.17), P=.0717; Anatomic outcomes:; - CRT, mean change at 12 months: -156.8 (SD 122.8) vs -129.8 (SD 114.8) vs -149.2 (SD 119.7) vs -138.5 (SD 122.2); P=NR; - Cystic intraretinal edema and subretinal fluid absent on OCT (“dry retina”):^b^ 80.3% vs 63.9% vs 71.9% vs 60.4%; P=NR | - Low ROB; - Non-inferiority study.
VIEW 1 and VIEW 2 combined 22-month results; Schmidt-Erfurth 2014^44^; - Active subfoveal CNV lesions or juxtafoveal lesions with leakage affecting the fovea, secondary to AMD; - 2457 (2412 analyzed); - 22 months (96 weeks); - 75.9 years (SD 8.6), 42.8% male, 53.8 letters (SD 13.6) | Group 1: Aflibercept 2.0 mg monthly for 12 months, capped PRN months 12-22 (n=617) Group 2: Aflibercept 0.5 mg^a^ monthly for 12 months, capped PRN months 12-22 (n=615) Group 3: Aflibercept 2.0 mg every other month (after 3 initial monthly doses) for 12 months, capped PRN months 12-22 (n=616) Group 4: Ranibizumab 0.5 mg monthly for 12 months, capped PRN months 12-22 (n=609); - Schedule: During follow-up period from 12 to 22 months, patients continued to receive the same dose of study drugs as in the first 12 months, but received injections at least every 12 weeks (capped PRN). | Aflibercept 2 mg monthly vs Aflibercept 0.5 mg^a^ monthly vs Aflibercept 2 mg bimonthly vs Ranibizumab 0.5 mg monthly Visual acuity outcomes:; - BCVA, mean change at 22 months: 7.6 vs 6.6 vs 7.6 vs 7.9; LS mean difference (confidence intervals estimated from a graph):; ▪ Group 1 vs Group 4: -0.2 (95% CI, -2.0 to 1.6); ▪ Group 2 vs Group 4: -1.28 (95% CI, -3.0 to 0.4); ▪ Group 3 vs Group 4: -0.25 (95% CI, -2.0 to 1.5); - % of participants gaining ≥15 letters at 22 months: 31.2% vs 28.1% vs 33.4% vs 31.6%; - % with BCVA of 20/40 (Snellen chart) or better at 22 months: 34.9% vs 30.7% vs 33.8% vs 34.5%; P=NR; Anatomic outcomes:; - CRT, mean change at 22 months: -128 vs -113 vs -133 vs -128; P=NR; - Retinal fluid absent on OCT at 22 months: 54.4% vs 44.6% vs 50.1% vs 45.5% | - Low ROB for both VIEW 1 and VIEW 2
Bevacizumab vs Ranibizumab
Biswas 2011^33^; - Choroidal neovascular membrane secondary to AMD; occult CNV 44%; - 120 (104 analyzed); - 18 months; - 63.9 years (SD NR), 48% male, 57.5 letters (SD NR) | Group 1: Bevacizumab 1.25 mg (n=60) Group 2: Ranibizumab 0.5 mg (n=60); - Schedule: Both groups injected monthly for 3 months, then PRN. | Bevacizumab vs Ranibizumab Visual acuity outcomes:; - BCVA, mean change:; ▪ 12 months: 0.52 vs 3.22; P=.463; ▪ 18 months: 3.96 vs 3.56; P=.563; - % of participants gaining ≥15 letters at 18 months: 12% vs 26%; P=NR; Anatomic outcomes:; - CMT, mean change:; ▪ 12 months: -26.44 vs -27.59; P=.283; ▪ 18 months: -37.96 vs -44.70; P=.281; Subgroup analyses found that mean BCVA change at 18 months was greater in the predominately classic subgroup than the group as a whole (5.4 vs 4.0 bevacizumab group; 5.2 vs 3.6 ranibizumab group). | - Unclear ROB
BRAMD (Bevacizumab to Ranibizumab in Patients with Exudative Age-Related Macular Degeneration); Schauwvlieghe 2016^45^; - Primary or recurrent sub- or juxtafoveal CNV secondary to AMD; - 332 (327 analyzed); - 12 months; - 78 years (SD 7), 44% male, 60 letters (SD 13) | Group 1: Bevacizumab 1.25 mg (n=166) Group 2: Ranibizumab 0.5 mg (n=166); - Schedule: Both groups injected monthly. | Bevacizumab vs Ranibizumab Visual acuity outcomes:; - BCVA, mean change at 12 months: 5.1 (SD 14.1) vs 6.4 (SD 12.2); P=.37; - % of participants gaining ≥15 letters at 12 months: 24% vs 19%; Anatomic outcomes:; - CRT, mean change at 12 months: -131 (SD 129) vs -138 (SD 117); P=.31; - Subretinal fluid and intraretinal cysts absent on OCT at 12 months: 44% vs 59%; P=.020 | - Low ROB; - Non-inferiority study.
CATT (Comparison of AMD Treatments Trials); Martin 2012^41,42^; - Previously untreated active CNV due to AMD; - 1208^c^ (1105 analyzed at 12 months, 1030 analyzed at 24 months); - 24 months; - 79.2 years (SD 7.5), 38.2% male, 60.6 letters (SD 13.5) | Group 1: Bevacizumab 1.25 mg monthly* (n=286) Group 2: Ranibizumab 0.5 mg monthly* (n=301) Group 3: Bevacizumab 1.25 mg PRN (n=300) Group 4: Ranibizumab 0.5 mg PRN (n=298); - Schedule: Monthly regimens were given an injection every 28 days; PRN regimens were given one initial injection and then only when signs of active neovascularization were present.; *Patients in the monthly groups were re-randomized at 12 months to either continue with monthly injections or switch to PRN (study drug not changed). | Bevacizumab monthly vs Ranibizumab monthly vs Bevacizumab PRN vs Ranibizumab PRN Visual acuity outcomes:; - BCVA, mean change:; ▪ 12 months: 8.0 (SD 15.8) vs 8.5 (SD 14.1) vs 5.9 (SD 15.7) vs 6.8 (SD 13.1); P=.16; - Estimated mean change (longitudinal regression model): 7.3 (SE 0.8) vs 7.2 (SE 0.7) vs 6.1 (SE 0.7) vs 6.4 (SE 0.6); P=.53; ▪ 24 months:^d^ 7.8 (SD 15.5) vs 8.8 (SD 15.9) vs 5.0 (SD 17.9) vs 6.7 (SD 14.6); P=.21 between drugs; - Estimated mean change (longitudinal regression model): 0.7 letters in favor of ranibizumab (95% CI, -0.9 to 2.3), P=.41; - % of participants gaining ≥15 letters:; ▪ 12 months: 31.3% vs 34.2% vs 28.0% vs 24.9%; P=.09; ▪ 24 months:^d^ 31.8% vs 32.8% vs 28.3% vs 30.7%; P=NR; - % of participants achieving Snellen equivalent of 20/40 or better (ETDRS >68 letters) at 24 months: 60.5% vs 67.9% vs 62.1% vs 63.3%; Anatomic outcomes:; - Total foveal thickness, mean change:; ▪ 12 months: -164 (SD 181) vs -196 (SD 176) vs -152 (SD 178) vs -168 (SD 186); P=.03 between all groups; ▪ 24 months: -180 (SD 196) vs -190 (SD 172) vs -153 (SD 189) vs -166 (SD 190); P=.38 between drugs; - Fluid absent on OCT:; ▪ 12 months: 26.0% vs 43.7% vs 19.2% vs 23.9%; P<.001; ▪ 24 months:^d^ 30.2% vs 45.5% vs 13.9% vs 22.3%; P=.0003 between drugs | - Low ROB; - Re-randomization: At 12 months, patients initially assigned to monthly treatment retained their drug assignment but were reassigned randomly to either monthly or PRN (results only recorded here for patients treated with the same dosing regimen for 2 years).
GEFAL (French Study Group Avastin versus Lucentis for Neovascular AMD trial); Kodjikian 2013^34^; - Active subfoveal neovascular AMD; - 501 (404 analyzed); - 12 months; - 79.2 years (SD 7.1), 33.7% male, 55.2 letters (SD 14.0) | Group 1: Bevacizumab 1.25 mg (n=255) Group 2: Ranibizumab 0.5 mg (n=246); - Schedule: Both groups injected monthly for 3 months, then PRN. | Bevacizumab vs Ranibizumab Visual acuity outcomes:; - BCVA, mean change at 12 months: 4.82 (SD 14.85) vs 2.93 (SD 15.09); mean difference -1.89 letters (95% CI, -1.16 to 4.9); - % of participants gaining ≥15 letters at 12 months: 20.4% vs 21.3%; P=.8318; Anatomic outcomes:; - CST, mean change at 12 months: -94.96 (SD 132.78) vs -107.23 (SD 103.25); P=.2725; - Intraretinal and subretinal fluid absent on OCT at 12 months: 50.5% vs 58.2%; P=.14 | - Unclear ROB; - Non-inferiority study.
IVAN (Inhibition of VEGF in Age-related choroidal Neovascularisation trial); Chakravarthy 2013^27,37,38^; - Active previously untreated neovascular AMD with neovascular lesion involving the center of the fovea; - 628 (610 analyzed); - 24 months; - 77.7 years (SD 7.4), 40% male, 61.4 letters (SD 15.3) | Group 1: Bevacizumab 1.25 mg monthly or PRN (n=305)^e^ Group 2: Ranibizumab 0.5 mg monthly or PRN (n=323); - Schedule: All groups received injections monthly for 3 months, then received injections according to their allocation group (monthly or PRN). | Bevacizumab vs Ranibizumab Visual acuity outcomes:; - BCVA, mean change:; ▪ 12 months: 4.7 (SD 12.5) vs 6.4 (SD 12.8); weighted mean difference -1.66 (95% CI, -3.83 to 0.50); ▪ 24 months: 4.1 (SD 13.5) vs 4.9 (SD 15.0); weighted mean difference -0.80 (95% CI, -3.26 to 1.66); - % of participants gaining ≥15 letters:; ▪ 12 months: 16% vs 23%; P=NR; ▪ 24 months: 16% vs 24%; P=NR; - Bailey-Love Near Word Visual acuity, mean at 24 months (logMAR): 0.61 vs 0.55; GMR 0.94 (95% CI, 0.85 to 1.04), P=.23; - Belfast Reading Speed, median at 24 months: 52.5 vs 50.9; mean difference -1.34 (95% CI, -8.29 to 5.61), P=.70; - Pelli-Robson Contrast Sensitivity, mean change at 24 months: 1.7 vs 1.5; mean difference 0.21 (95% CI, -0.62 to 1.04), P=.62; QOL outcomes:; - EQ-5D Utility Index, median change at 24 months: -0.15 (IQR -0.27 to 0.00) vs -0.15 (IQR -0.27 to 0.00); score of 1 (“perfect health”) OR 0.89 (95% CI, 0.64 to 1.25), P=.51; - MacDQoL, median at 24 months: -1.39 (IQR -2.73 to -0.41) vs -1.45 (IQR -2.77 to -0.27); GMR 1.05 (95% CI, 0.78 to 1.42), P=.74; - MacTSQ treatment satisfaction index, median at 24 months: 65.00 (IQR 60.00 to 69.00) vs 66.00 (IQR 61.50 to 70.00); OR 0.79 (95% CI, 0.54 to 1.16), P=.23; Anatomic outcomes:; - Total foveal thickness, mean change at 24 months: -133.8 (SD 205.0) vs -146.9 (SD 177.4); GMR 0.96 (95% CI, 0.90 to 1.03), P=.24; - Fluid absent on OCT at 24 months: 41% vs 50%; OR 0.72 (95% CI, 0.50 to 1.02), P=.065; Subgroup analyses^f^ found no significant differences for the drug or treatment regimen comparisons (P≥.26). | - Low ROB
LUCAS (Lucentis Compared to Avastin Study); Berg 2015^39,40^; - Previously untreated active neovascular AMD; - 441 (431 analyzed); - 24 months; - 78.3 years (SD 7.9), 32.5% male, 61.0 letters (SD 13.5) | Group 1: Bevacizumab 1.25 mg (n=220)^g^ Group 2: Ranibizumab 0.5 mg (n=221)^g^; - Schedule: “Treat-and-extend” -patients in both groups were injected every 4 weeks until no signs of active AMD were found, at which point the period to the next treatment was extended by 2 weeks at a time, up to a maximum interval of 12 weeks. If examination showed any sign of recurrence, the interval was shortened by 2 weeks at a time, until the disease was considered to be inactive. Interval extension was then restarted, with the maximum final interval being 2 weeks less than the period when the previous recurrence. | Bevacizumab vs Ranibizumab Visual acuity outcomes:; - BCVA, mean change (ITT analysis):; ▪ 12 months: 7.8 vs 8.0; mean difference 0.2 (95% CI, -2.2 to 2.5), P=.550; ▪ 24 months: 7.8 vs 7.5; mean difference -0.3 (95% CI, -3.2 to 2.7), P=.873; - % of participants gaining ≥15 letters:; ▪ 12 months: 25.5% vs 26.7%; P=NR; ▪ 24 months: 29.9% vs 29.1%; P=NR; Anatomic outcomes:; - CRT plus subfoveal fluid, mean change (ITT analysis):; ▪ 12 months: -108 (SD 102) vs -111 (SD 96); mean difference 3 (95% CI, -16 to 22), P=.265; ▪ 24 months: -111 (SD 116) vs -112 (SD 105); mean difference 1 (95% CI , -22 to 20), P=.923; - Fluid absent on OCT (intraretinal or subretinal):; ▪ 12 months: 47.0% vs 65.2%; P<.001; ▪ 24 months: 55.1% vs 72.1%; P<.001 | - Low ROB; - Non-inferiority study.
MANTA (Multicenter Anti-VEFG Trial in Austria); Krebs 2013^35^; - Active primary or recurrent subfoveal lesion with CNV secondary to AMD; - 317 (number analyzed unclear); - 12 months; - 77.2 years (SD 8.0), 36.3% male, 56.7 letters (SD 13.3) | Group 1: Bevacizumab 1.25 mg (n=154) Group 2: Ranibizumab 0.5 mg (n=163); - Schedule: Both groups injected monthly for 3 months, then PRN. | Bevacizumab vs Ranibizumab Visual acuity outcomes:; - BCVA, mean change at 12 months: 4.9 vs 4.1; P=.78; - % of participants gaining ≥15 letters: 23% vs 21%; P=.42; Anatomic outcomes:; - CRT, mean change at 12 months:^i^ -86.3 vs -89.9; P=.81 | - Unclear ROB; - Non-inferiority study.
Scholler 2014^29^; - Active previously untreated neovascular AMD; - 55 (number analyzed unclear); - 12 months; - 80.1 years (SD 6.7), 29.1% male, 58.0 letters (SD 11.7) | Group 1: Bevacizumab 1.25 mg (n=29) Group 2: Ranibizumab 0.5 mg (n=26); - Schedule: Both groups injected monthly for 3 months, then PRN. | Bevacizumab vs Ranibizumab Visual acuity outcomes:; - BCVA, mean change^j^ at 12 months: 7.3 (SD 15.3) vs 0.6 (SD 14.6); mean difference in BCVA achieved 5.5 letters, P=.631; Anatomic outcomes:; - Mean CRT at 12 months: 350.47 (SD 102.84) vs 315.67 (SD 65.86); P=.088 | - High ROB
Subramanian 2010^26^; - Symptomatic CNV affecting the foveal center; 18% classic or predominantly classic CNV; - 28 (22 analyzed); - 12 months; - 78.6 years, 95% male, 34.2 letters | Group 1: Bevacizumab (dose NR; n=20) Group 2: Ranibizumab (dose NR; n=8); - Schedule: Both groups injected monthly for 3 months, then PRN | Bevacizumab vs Ranibizumab Visual acuity outcomes:; - BCVA, mean change at 12 months:^k^ 7.6 vs 6.3; P=.74; - % of participants gaining ≥15 letters: 33% vs 14%; P=NR; Anatomic outcomes:; - CMT, mean change at 12 months: -50 vs -91; P=.29 | - High ROB; - VA population

Abbreviations: AMD = age-related macular degeneration; BCVA = best-corrected visual acuity; CI = confidence interval; CNV = choroidal neovascularization; CRT = central retinal thickness; CST = central subfield thickness; DME = diabetic macular edema; EQ-5D = European Quality of Life-5 Dimensions; ETDRS = Early Treatment of Diabetic Retinopathy Study; GMR = geometric mean ratio; IQR = interquartile range; ITT = intention-to-treat; logMAR = Logarithm of the Minimal Angle of Resolution; LS = least squares; MacDQoL = Macular Disease-dependent Quality of Life; MacTSQ = Macular Disease Treatment Satisfaction Questionnaire; NEI VFQ-25 = 25-item National Eye Institute Visual Functioning Questionnaire; NR = not reported; OCT = optical coherence tomography; OR = odds ratio; PRN = pro re nata (“as needed”); QOL = quality of life; ROB = risk of bias; SD = standard deviation; VEGF = vascular endothelial growth factor.

a Recommended dose is 2.0 mg.

b Post hoc analysis.

c The trial randomized 1208 patients, but 23 patients at one study center were later excluded because of serious protocol noncompliance.^41^

d Participants treated with the same regimen for 2 years (rather than switching from monthly injections to PRN at 12 months).

e Results were reported both by drug and treatment schedule; however, as our key questions were not looking at effectiveness according to dosing schedule, only drug comparisons are reported here.

f Subgroup analyses were performed for: baseline BCVA in fellow eye, baseline retinal angiomatous proliferation, baseline lesion, baseline choroidal neovascularization size, baseline BCVA, hemorrhage was present at baseline, study eye ≥ 5 letters better than in the fellow eye at baseline.

g Patients who developed wet AMD in the non-study eye received the same drug in both eyes; 31 patients in Group 1 and 25 patients in Group 2 were treated in both eyes.

h Figures estimated from a graph.

i Corrected values, converted to compensate for different OCT machines used.

j Calculated based on data reported by the study (baseline and BCVA achieved).

k For this study, BCVA was measured using ETDRS at 2 m instead of the recommended 4 m because of examination room size; vision was recorded in the same fashion for all study subjects in both treatment arms.

##### Aflibercept versus Ranibizumab

Two large collaborative studies (VIEW 1 and VIEW 2)^43^ with low ROB compared aflibercept to ranibizumab in patients with AMD. The studies had equivalent designs but VIEW 1 (N=1217) was conducted in the US and Canada, and VIEW 2 (N=1240) was conducted in several European, Middle Eastern, Asian-Pacific, and Latin American countries. While the study compared 3 different dosages of aflibercept (2.0 mg monthly, 0.5 mg monthly, and 2.0 mg every other month after 3 monthly doses) with monthly ranibizumab, we focused on the results using the standard dose of aflibercept (2.0 mg) administered monthly, for comparability to the ranibizumab arm and other studies.

Visual Outcomes. The VIEW 1 trial found a small, statistically significant difference in favor of monthly aflibercept compared to monthly ranibizumab in mean change in BCVA at 12 months (LS mean difference 3.15 letters [95% CI, 0.92 to 5.37], P = .0054), while VIEW 2 conversely found a small benefit with monthly ranibizumab, though the difference did not reach statistical significance (LS mean difference -1.95 [95% CI, -4.10 to 0.20], P = .076). Interestingly, VIEW 2 also reported that aflibercept administered every other month had a numerically higher mean BCVA change than monthly aflibercept (8.9 vs 7.6 letters, P-value not reported), although the reason and significance of this finding is uncertain. Due to inconsistent results between the trials, a meta-analysis combining the 2 studies found considerable statistical heterogeneity (I^2^ = 90.4%) despite their equivalent protocols. The studies were conducted in different countries, but the reasons for the conflicting findings are otherwise unclear.

Similar results were found in the percentage of participants gaining 15 or more ETDRS letters from baseline to 12 months, with VIEW 1 showing a slight advantage in favor of aflibercept and VIEW 2 in favor of ranibizumab, although neither study found a significant difference between the drugs (VIEW 1: P = .1042; VIEW 2: P = .229). The vast majority of participants in all groups did not lose more than 15 letters (∼95% at 12 months and ∼92% at 22 months), and approximately 80% of participants either improved or maintained their BCVA (gained 0 or more letters) at 12 months. An analysis combining both studies at 22 months^44^ found a slight decline in visual acuity from 12 months, possibly as a result of switching from monthly injections to PRN, but there was no difference between aflibercept and ranibizumab in mean change in BCVA (mean difference 0.20 letters [95% CI, -1.55 to 1.95]) or in percentage of patients gaining 15 or more letters (31.2% for aflibercept monthly vs 31.6% for ranibizumab monthly). VIEW 1 and VIEW 2, as well as the combined 22-month results, found no significant differences in visual acuity between groups receiving bimonthly aflibercept and those receiving monthly ranibizumab.

Quality of Life Outcomes. In terms of vision-related quality of life, both VIEW 1 and VIEW 2 reported improved scores on the 25-item National Eye Institute Visual Functioning Questionnaire (NEI VFQ-25) among all groups. VIEW 2 found a statistically significant advantage for monthly ranibizumab over monthly aflibercept (LS mean difference -2.79 [95% CI, -4.90 to -0.68], P = .0097), but VIEW 1 found no significant difference between the drugs (LS mean difference 1.28 in favor of aflibercept [95% CI, -0.73 to 3.28], P = .2090).

Anatomic Outcomes. Both studies reported a significant decrease from baseline in central retinal thickness at both 12 and 22 months (> 110 μm for all groups in both studies), although statistical comparisons between groups were not reported.

##### Bevacizumab vs Ranibizumab

Nine trials (combined N=3630) compared bevacizumab to ranibizumab in patients with AMD (4 with low ROB,^27,37-39,41,42,45^ 3 with unclear ROB,^33-35^ and 2 with high ROB^26,29^). Six of the studies included over 300 participants, and all but one trial^45^ used PRN scheduling alone (although specific re-treatment criteria varied) or in addition to groups receiving monthly injections. Most trials followed patients for 12 months, although 3 studies had 24 months of follow-up^37,38,40,42^ and one study had 18 months of follow-up.^33^ All trials had a mean baseline BCVA between 55 and 62 ETDRS letters with the exception of one very small study (N=28)^26^, which included patients with substantially lower baseline visual acuity (mean 34.2 letters).

Visual Outcomes. No individual study comparing bevacizumab with ranibizumab found a significant difference between drugs in mean change in BCVA. Meta-analyses pooling the results of the trials also found no differences between the drugs at 12 months (pooled mean difference -0.218 letters in favor of ranibizumab [95% CI, -1.431 to 0.995], P = .725; Figure 2), or at 18 to 24 months (-0.126 letters [95% CI, -1.033 to 0.781], P = .785; Figure 3).

Figure 2 Mean change in BCVA at 12 months in AMD patients treated with bevacizumab vs ranibizumab

a Numbers reported for CATT are from the group randomized to monthly injections only.

Figure 3 Mean change in BCVA at 18-24 months in AMD patients treated with bevacizumab vs ranibizumab

a Numbers reported for CATT are from the group randomized to monthly injections only.

The proportion of patients gaining 15 or more ETDRS letters from baseline varied considerably across the trials, ranging from 12% to 34%. A slightly greater proportion of patients treated with ranibizumab compared to bevacizumab achieved this outcome at 12 months (RR 0.930 [95% CI, 0.804 to 1.075], P = .325; Figure 4) and at 18 to 24 months (RR 0.835 [95% CI, 0.630 to 1.107], P = .210; Figure 5), but the differences did not reach statistical significance at either timepoint. The majority of patients in all trials were able to either improve or maintain their vision (within 5 ETDRS letters) throughout the trial (66% to 92%).

Figure 4 Likelihood of gaining 15 or more letters at 12 months in AMD patients treated with bevacizumab vs ranibizumab

a Numbers reported are from the group randomized to monthly injections only.

Figure 5 Likelihood of gaining 15 or more letters at 18-24 months in AMD patients treated with bevacizumab vs ranibizumab

a Numbers reported are from the group randomized to monthly injections only.

The largest trial (low ROB) was the Comparison of AMD Treatments Trials (CATT),^41,42^ which randomized 1208 participants to either bevacizumab or ranibizumab administered either monthly or PRN. Groups remained on the allocated drug for the entire 24-month period, but groups originally randomized to monthly regimens were re-randomized at 12 months to either continue receiving monthly injections or switch to PRN dosing. At 24 months, there was no statistically significant difference in mean change in BCVA between the drugs (P = .21; P = .41 after adjusting for baseline predictors in the multivariate longitudinal regression model), but the monthly injection regimen was superior to PRN dosing (P = .046; P = .07 in the multivariate longitudinal regression model). In fact, patients who switched from receiving monthly injections in the first year to receiving injections as needed lost a mean of 2.2 letters in the second year of the trial. All groups achieved a mean BCVA of over 66 ETDRS letters at both 12 and 24 months, and over 60% of all groups achieved a BCVA of 68 or more letters at 24 months.

Four other relatively large studies (IVAN, N=628; LUCAS, N=441; BRAMD, N=327; MANTA, N=321) with low ROB similarly found no significant difference between drugs in mean change in BCVA from baseline.^27,35,37-40,45^ The IVAN trial reported that 16% of patients receiving bevacizumab and 24% receiving ranibizumab gained 15 or more ETDRS letters from baseline; however, statistical significance testing was not reported. The other 3 studies reported 21% to 27% of participants gaining 15 or more letters, with no significant differences found between groups. The LUCAS, IVAN, and BRAMD trials reported mean BCVA at 12 months in the range of 65 to 70 ETDRS letters, while MANTA reported a slightly lower achieved mean BCVA (61.4 letters). The 2 trials assessing longer-term outcomes reported a similar achieved BCVA at 24 months (66 to 68 letters).

Quality of Life Outcomes. IVAN was the only trial reporting quality of life outcomes, and it found no difference between groups in general health-related quality of life (European Quality of Life-5 Dimensions [EQ-5D], P = .51) or macular degeneration-related quality of life (Macular Disease-dependent Quality of Life [MacDQoL], P = .74). Treatment satisfaction was also similar between groups (Macular Disease Treatment Satisfaction Questionnaire [MacTSQ], P = .23).

Anatomic Outcomes. Reporting of anatomic outcomes varied significantly, so it is difficult to summarize findings across studies. However, most studies found a significant decrease from baseline in central foveal, retinal, or subfield thickness. No study reported significant differences between drugs.

Differences between drugs were reported in several trials regarding the percentage of patients with no fluid present on OCT imaging. Several studies found ranibizumab statistically superior to bevacizumab for this outcome, including CATT (45.5% vs 30.2% at 24 months, P = .0003), LUCAS (55.1% vs 72.1% at 24 months, P < .001), and BRAMD (44% vs 59% at 12 months, P = .020); the other 2 studies reporting this outcome found no significant differences between the drugs (GEFAL, P = .14; IVAN, P = .065).

#### Diabetic Macular Edema (DME)

We found 3 eligible trials (808 total participants) comparing anti-VEGF agents for DME (one with low ROB, 2 with high ROB). One large trial (DRCR.net Protocol T, N=660) with low ROB compared all 3 anti-VEGF agents over 24 months (patients were also administered focal/grid laser photocoagulation rescue treatment if DME persisted after 6-months of injections),^46,47^ and 2 smaller studies with high ROB compared bevacizumab to ranibizumab at 12 months.^30,31^ One of these trials used a higher than typical dose of bevacizumab (1.5 mg, rather than the recommended 1.25 mg),^31^ and another trial reported using 0.05 mg of ranibizumab (possibly a reporting error).^30^ All studies used variations of PRN dosing, although specific criteria for retreatment varied between studies. Participants had a mean age of 60 to 67 years at baseline. None of the trials reported quality of life outcomes; one study calculated some quality of life outcomes based on reported visual acuity and adverse events, rather than using a validated measure of quality of life, and thus this outcome was not abstracted (although the calculated data was used in cost analyses reported in Key Question 3).^48^ Study details are found in Table 3 (additional study information is provided in Appendix D).

Table 3 Effectiveness of Anti-VEGF Agents for DME

Trial name; Author, year; - Population; - Number randomized; - Length of follow-up; - Population characteristics: mean age, % male, mean baseline BCVA | Interventions Groups (number per group); - Treatment schedule | Main Outcomes:; - Visual acuity (reported as ETDRS chart letters unless otherwise indicated); - Quality of life (QOL) measures; - Anatomic outcomes (reported in μm unless otherwise indicated) | Notes; - ROB; - Other notes
Aflibercept vs Bevacizumab
DRCR.net (Diabetic Retinopathy Clinical Research Network) Protocol T;^a^ Wells 2016^46,47^; - DME involving the macular center; - 660 (578 analyzed at 24 months); - 24 months; - 60.6 years (SD 10), 54% male, 64.8 letters (SD 11.3) | Group 1: Aflibercept 2.0 mg PRN (n=224) Group 2: Bevacizumab 1.25 mg PRN (n=218); - Schedule: Both groups injected every 4 weeks unless visual acuity was 20/20 or better, CST was below the eligibility threshold, and no improvement or worsening observed in response to 2 consecutive injections.; - Patients also received focal/grid laser photocoagulation starting at 6-months if DME persisted. | Aflibercept vs Bevacizumab Visual acuity outcomes:; - BCVA, mean change:; ▪ 12 months: 13.3 (SD 11.1) vs 9.7 (SD 10.1); mean difference 3.5 (95% CI, 1.4 to 5.7), P<.001; ▪ 24 months: 12.8 (SD 12.4) vs 10.0 (SD 11.8); mean difference 2.7 (95% CI, 0.3 to 5.2), P=.02; Subgroup analyses found a significant difference in mean change in BCVA between aflibercept and bevacizumab in participants with baseline BCVA < 69 letters at 12 months (mean difference 6.5 letters [95% CI, 2.9 to 10.1] in favor of aflibercept; P<001) and 24 months (mean difference 4.7 letters [95% CI, 0.5 to 8.8]; P=.02), but found no difference in participants with baseline BCVA 69-78 letters at either timepoint (12 months P=.69; 24 months P=.51).; - % of participants gaining ≥15 letters:; ▪ 12 months: 42% vs 29%; P=.028; ▪ 24 months: 39% vs 35%; P=.70; Subgroup analyses reported a significant difference in percentage of patients gaining ≥15 letters in the group with lower baseline BCVA at 12 months (67% vs 41%, P<.001) but not 24 months (58% vs 52%, P=.74). No difference was found at either timepoint in the group with higher baseline BCVA (12 months P=.73; 24 months P=.89). Anatomic outcomes:; - CST, mean change:; ▪ 12 months: -169 (SD 138) vs -101 (SD 121); P<.001; ▪ 24 months: -171 (SD 141) vs -126 (SD 143); P<.001 | - Low ROB
Aflibercept vs Ranibizumab
DRCR.net (Diabetic Retinopathy Clinical Research Network) Protocol T;^a^ Wells 2016^46,47^; - DME involving the macular center; - 660 (578 analyzed at 24 months); - 24 months; - 60.6 years (SD 10), 54% male, 64.8 letters (SD 11.3) | Group 1: Aflibercept 2.0 mg PRN (n=224) Group 3: Ranibizumab 0.3 mg PRN (n=218); - Schedule: Both groups injected every 4 weeks unless visual acuity was 20/20 or better, CST was below the eligibility threshold, and no improvement or worsening observed in response to 2 consecutive injections.; - Patients also received focal/grid laser photocoagulation starting at 6-months if DME persisted. | Aflibercept vs Ranibizumab Visual acuity outcomes:; - BCVA, mean change:; ▪ 12 months: 13.3 (SD 11.1) vs 11.2 (SD 9.4); mean difference 2.1 (95% CI, 0.1 to 4.2), P= .034; ▪ 24 months: 12.8 (SD 12.4) vs 12.3 (SD 10.5); mean difference 0.7 (95% CI, -1.3 to 2.8), P=.47; Subgroup analyses found a significant difference in mean change in BCVA between aflibercept and ranibizumab in participants with baseline BCVA <69 letters at 12 months (mean difference 4.7 letters [95% CI, 1.4 to 8.0] in favor of aflibercept, P=.003) but not 24 months (P=. 18). In patients with baseline BCVA 69-78 letters, no significant differences were found at either timepoint (12 months P=.69; 24 months P=.51).; - % of participants gaining ≥15 letters:; ▪ 12 months: 42% vs 32%; P=.068; ▪ 24 months: 39% vs 37%; P=.70; Subgroup analyses reported a significant difference in percentage of patients gaining ≥15 letters in the group with lower baseline BCVA at 12 months (67% vs 50%, P=.008) but not 24 months (58% vs 55%, P=.75). No difference was found at either timepoint in the group with higher baseline BCVA (12 months P=.73; 24 months P=.89). Anatomic outcomes:; - CST, mean change:; ▪ 12 months: -169 (SD 138) vs -147 (SD 134); P=.036; ▪ 24 months: -171 (SD 141) vs -149 (SD 141); P=.08 | - Low ROB
Bevacizumab vs Ranibizumab
DRCR.net (Diabetic Retinopathy Clinical Research Network) Protocol T;^a^ Wells 2016^46,47^; - DME involving the macular center; - 660 (578 analyzed at 24 months); - 24 months; - 60.6 years (SD 10), 54% male, 64.8 letters (SD 11.3) | Group 2: Bevacizumab 1.25 mg PRN (n=218) Group 3: Ranibizumab 0.3 mg PRN (n=218); - Schedule: Both groups injected every 4 weeks unless visual acuity was 20/20 or better, CST was below the eligibility threshold, and no improvement or worsening observed in response to 2 consecutive injections.; - Patients also received focal/grid laser photocoagulation starting at 6-months if DME persisted. | Bevacizumab vs Ranibizumab Visual acuity outcomes:; - BCVA, mean change:; ▪ 12 months: 9.7 (SD 10.1) vs 11.2 (SD 9.4); mean difference 1.4 (-0.4 to 3.2), P=.12; ▪ 24 months: 10.0 (SD 11.8) vs 12.3 (SD 10.5); mean difference 2.0 (95% CI, -0.4 to 4.4), P=. 11; Subgroup analyses found no significant differences in mean change in BCVA between bevacizumab and ranibizumab in participants with baseline BCVA < 69 (12 months P=.21; 24 months P=.18) nor in patients with baseline BCVA 69-78 letters (12 months P=.69; 24 months P=.31).; - % of participants gaining ≥15 letters:; ▪ 12 months: 29% vs 32%; P=.51; ▪ 24 months: 35% vs 37%; P=.70; Subgroup analyses found no significant differences in percentage of patients gaining ≥15 letters in the group with lower baseline BCVA or the group with higher baseline BCVA at 12 or 24 months. Anatomic outcomes:; - CST, mean change:; ▪ 12 months: -101 (SD 121) vs -147 (SD 134); P<.001; ▪ 24 months: -126 (SD 143) vs -149 (SD 141); P<.001 | - Low ROB
Ekinci 2014^30^; - Clinically significant DME; - 100 (85 analyzed); - 12 months; - 66.5 years (SD 11.5), 36% male, 0.23 Snellen chart letters (SD 0.12) | Group 1: Bevacizumab 1.25 mg (n=50) Group 2: Ranibizumab 0.05 mg^b^ (n=50); - Schedule: Both groups injected monthly for 3 months, then PRN. Additional monthly doses were administered if CMT was >275 μm or if BCVA increased by ≥3 letters compared with baseline. | Bevacizumab vs Ranibizumab Visual acuity outcomes:; - BCVA, mean change at 12 months (converted from the Snellen chart to ETDRS letters) ^c^: 12 (SD 16.6) vs 10 (SD 16.4); P=NS; Anatomic outcomes:; - Mean foveal thickness at 12 months: 342.3 (SD 121) vs 339.3 (SD 121); P=NS | - High ROB; - The study excluded patients with certain AEs during follow-up (acute ocular infection, stroke, MI, uncontrolled hypertension, pregnancy, renal failure and cataract formation).
Nepomuceno 2013^31^; - DME with central involvement; - 63 eyes in 48 patients (60 eyes in 45 patients analyzed)^d^; - 11 months (48 weeks); - 63.8 years (SE 8.9), 45% male, 0.62 logMAR (SE 0.06) [approximately equivalent to 68 ETDRS letters]^28^ | Group 1: Bevacizumab 1.5 mg^e^ PRN (n=34 eyes) Group 2: Ranibizumab 0.5 mg^f^ PRN (n=29 eyes); - Schedule: Both groups received injection monthly if CST was >275 μm. | Bevacizumab vs Ranibizumab Visual acuity outcomes:; - BCVA, mean change at 11 months (logMAR): -0.23 (SD 0.02) vs -0.29 (SD 0.04) [approximately equivalent to 11 vs 13 ETDRS letters] ^28^; P=.1886; - % of participants gaining ≥15 letters: 39% vs 48%; P=NS; Anatomic outcomes:; - Maximum mean CST reduction: -126 (SE 25) at week 48 vs -136 (SE 23) at week 44; P=NS; A multivariate analysis comparing BCVA and CST outcomes between the bevacizumab and ranibizumab groups, taking into account number of injections, baseline BCVA, and CST, demonstrated a statistically significant influence of baseline BCVA on follow-up BCVA (P < .001). | - High ROB

Abbreviations: BCVA = best-corrected visual acuity; CI = confidence interval; CMT = central macular thickness; CST = central subfield thickness; DME = diabetic macular edema; ETDRS = Early Treatment Diabetic Retinopathy Study; logMAR = Logarithm of the Minimal Angle of Resolution chart; MI = myocardial infarction; NS = not significant; PRN = pro re nata (“as needed”); QOL = quality of life; ROB = risk of bias; SD = standard deviation; SE = standard error; VEGF = vascular endothelial growth factor.

a This trial involved 3 groups; thus, it is listed under each two-way comparisons.

b Ranibizumab 0.05 mg is the dose reported in the published study (potentially an error); the recommended dose is 0.3 mg for patients with DME.

c The study did not report mean change, so we calculated it by converting the baseline and achieved BCVA based on the Snellen chart to ETDRS letters.28. Colenbrander A, International Council of Ophthalmology. Visual Standards: Aspects and Ranges of Vision Loss (with Emphasis on Population Surveys). 2002; http://www.icoph.org/downloads/visualstandardsreport.pdf. Accessed December 28, 2016 .

d If both eyes were eligible for treatment and the patient agreed to treat both eyes with anti-VEGF therapy, one eye received the randomized treatment according to a computer-generated sequence and the contralateral eye received the other anti-VEGF agent on the next day.

e The standard recommended dose is 1.25 mg.

f The recommended dose of ranibizumab for DME is 0.3 mg; however, 0.5 mg is the standard dose for both AMD and BRVO/CRVO.

##### Aflibercept vs Bevacizumab

Visual Outcomes. DRCR.net Protocol T found that aflibercept was statistically significantly superior to bevacizumab in mean change in BCVA at both 12 months (mean difference 3.5 letters [95% CI, 1.4 to 5.7], P < .001) and 24 months (mean difference 2.7 letters [95% CI, 0.3 to 5.2], P = .02).^46,47^ However, the difference between drugs was small (less than 5 ETDRS letters) at both timepoints and likely not clinically important. The trial reported that both groups achieved a mean BCVA equivalent to 20/32 or better on the Snellen chart at 12 months that continued through 24 months (aflibercept 77.8 vs bevacizumab 74.6 letters, P-value not reported). The aflibercept group had a significantly greater proportion of participants gaining 15 or more ETDRS letters compared to bevacizumab at 12 months (42% vs 29%, P = .028), but there was no difference between the groups by 24 months (39% vs 35%, P = .70).

Subgroup analyses from the DRCR.net Protocol T trial found significant differences in mean BCVA change according to baseline visual acuity. There was a statistically significant and clinically meaningful advantage of aflibercept over bevacizumab in participants with lower baseline visual acuity (BCVA of less than 69 ETDRS letters) at 12 months (mean difference in BCVA change 6.5 letters [95% CI, 2.9 to 10.1], P < .001); the difference was significant but smaller by 24 months (4.7 letters [95% CI, 0.5 to 8.8], P = .02). Similarly, there was a significantly greater percentage of patients in the aflibercept group gaining 15 or more letters at 12 months (67% vs 41%, P < .001), although by 24 months there was no difference between the drugs (58% vs 52%, P=.74). In contrast, among patients with higher baseline acuity (69 to 78 ETDRS letters), there was no difference between the drugs at either timepoint with respect to proportion of patients gaining 15 or more letters or mean change in BCVA (mean difference 1.1 letters [95% CI, -1.1 to 3.4]) at 24 months, P = .51).^46,47^

Anatomic Outcomes. There was a statistically significant difference favoring aflibercept in mean change in central subfield at both 12 months (169 μm vs 101 μm decrease, P < .001) and 24 months (171 μm vs 126 μm decrease, P < .001).

##### Aflibercept vs Ranibizumab

Visual Outcomes. DRCR.net Protocol T reported a statistically significant advantage with aflibercept over ranibizumab in mean change in BCVA at 12 months (mean difference 2.1 letters [95% CI, 0.1 to 4.2], P = .034), but not at 24 months (0.7 letters [95% CI, -1.3 to 2.8], P = .47); however, the difference was small and likely not clinically meaningful.^46,47^ Both groups achieved a mean BCVA of over 77 letters (trial-reported Snellen equivalent 20/32) at 12 and 24 months. There was a marginally significant difference in the proportion of participants gaining 15 or more ETDRS letters in the aflibercept group compared to the ranibizumab group at 12 months (42% vs 32%, P = .068), but there was no difference between the drugs at 24 months (39% vs 37%, P = .70).

The superiority of aflibercept to ranibizumab was more pronounced in a subgroup of participants with lower baseline BCVA (less than 69 ETDRS letters) at 12 months (mean difference in BCVA change 4.7 letters [95% CI, 1.4 to 8.0], P = .003), but not at 24 months (2.3 letters [95% CI, -1.1 to 5.6], P = .18). Similar results were found for the percentage of patients gaining 15 or more letters from baseline; significantly more patients in the aflibercept group compared to ranibizumab achieved this outcome at 12 months (P = .008), but no difference was found between the groups at 24 months (P = .75). There was no difference between the drugs in patients with higher baseline BCVA (69 to 78 ETDRS letters) at either 12 or 24 months (mean difference in BCVA change 0.7 letters [95% CI, -2.9 to 1.5], P = .51).

Anatomic Outcomes. We found a small difference in favor of aflibercept with regard to mean change in central subfield difference at 12 months (169 μm vs 147 μm decrease, P = .036), and the change in reduction neared significance at 24 months (171 μm vs 149 μm decrease, P = .08).

##### Bevacizumab vs Ranibizumab

Visual Outcomes. The 3 studies comparing bevacizumab to ranibizumab (one trial using a 1.5 mg dose) as well as meta-analyses combining the studies found no significant differences between the drugs at 12 months with regard to mean change in BCVA (pooled mean difference -1.190 [95% CI, -2.889 to 0.509], P = .170; Figure 6) or in the proportion of participants gaining 15 or more letters from baseline (RR 0.871 [95% CI, 0.670 to 1.133], P = .304; Figure 7).^30,31,46,47^ DRCR.net Protocol T also reported values at 24 months and found no difference between drugs (P = .11 for mean change in BCVA, and P = .70 for percentage gaining 15 or more letters).^46,47^ Subgroup analyses also showed no significant differences between drugs at either 12 months or 24 months among participants with lower baseline visual acuity or with higher baseline visual acuity.

Figure 6 Mean change in BCVA at 12 months in DME patients treated with bevacizumab vs ranibizumab

Figure 7 Likelihood of gaining 15 or more letters at 18-24 months in DME patients treated with bevacizumab vs ranibizumab

a Data are for number of eyes rather than number of patients, since for this trial patients with both eyes meeting eligibility criteria received different drugs in each eye.

Anatomic Outcomes. The largest trial comparing bevacizumab to ranibizumab found a statistically significant difference in mean decrease in central subfield thickness in favor of ranibizumab at both 12 months (147 μm vs 101 μm; P < .001) and 24 months (149 μm vs 126 μm; P <.001), however the clinical significance of this difference is unclear.^46,47^ The 2 smaller trials did not find a significant difference in mean foveal thickness^30^ or mean reduction in central subfield thickness^31^ at 12 months.

#### Macular Edema due to Central Retinal Vein Occlusion (CRVO) or Branch Retinal Vein Occlusion (BRVO)

Two small trials, MARVEL (unclear ROB)^36^ and CRAVE (high ROB),^32^ examined anti-VEGF agents in 177 total patients with RVO (Table 4; additional study information is provided in Appendix D). CRAVE included patients with either CRVO or BRVO, and MARVEL included BRVO patients only. Participants in the MARVEL study were significantly younger, with an average age 20 years younger than participants in the CRAVE trial. Both studies compared bevacizumab to ranibizumab at 6 months, but one study used a monthly injection regimen and the other study used PRN dosing. Neither study assessed quality of life outcomes.

Table 4 Effectiveness of Anti-VEGF Agents for Macular Edema due to CRVO or BRVO

Trial name; Author, year; - Population; - Number randomized; - Length of follow-up; - Population characteristics: mean age, % male, mean baseline BCVA | Interventions Groups (number per group); - Treatment schedule | Main Outcomes:; - Visual acuity (reported as ETDRS chart letters unless otherwise indicated); - Quality of life (QOL) measures; - Anatomic outcomes (reported in μm unless otherwise indicated) | Notes; - ROB; - Other notes
Bevacizumab vs Ranibizumab
CRAVE (Comparison of Anti-VEGF Agents in the Treatment of Macular Edema from Retinal Vein Occlusion Trial); Rajagopal 2015^32^; - Macular edema secondary to RVO (60% of patients with BRVO or hemi-RVO, 40% with central RVO); - 102^a^ (98 analyzed); - 6 months; - 71.5 years (SD 12), 44.9% female, 0.745 logMAR (SD 0.42) | Group 1: Bevacizumab 1.25 mg monthly (n=51)^a^ Group 2: Ranibizumab 0.5 mg monthly (n=51); - Schedule: Both groups received monthly injections for 6 months. | Bevacizumab vs Ranibizumab Visual acuity outcomes:; - BCVA (Snellen chart), mean change at 6 months (logMAR): 0.33 (SD 0.45) vs 0.34 (SD 0.33); P=.38; - % of participants gaining ≥0.3 logMAR units at 6 months: 71.4% vs 70.6%; P=.94; Anatomic outcomes:; - Central foveal thickness, mean change at 6 months: : -212.6 (SD 234.8) vs -243.8 (SD 204.2); P=.72; - Fluid absent on OCT at 6 months: 56.3% vs 51.4%; P=.81; Subgroup analyses observed no differences between drugs among BRVO or CRVO subsets in change in BCVA (BRVO: P=. 15; CRVO: P=.73) or central foveal thickness changes (BRVO: P=.37; CRVO: P=.92). | - High ROB
MARVEL; Narayanan 2015^36^; - Center-involving macular edema due to BRVO; - 75 (75 analyzed); - 6 months; - 51.7 years (SD 8.6), 54.6% male, 54.4 letters (SD 12.2) | Group 1: Bevacizumab 1.25 mg PRN (n=38) Group 2 Ranibizumab 0.5 mg PRN (n=37); - Schedule: Both groups injected at baseline then PRN. | Bevacizumab vs Ranibizumab Visual acuity outcomes:; - BCVA, mean change at 6 months: 15.6 vs 18.1; mean difference -2.5 letters (95% CI, -8.0 to 5.0), P=.74; - % of participants gaining ≥15 letters at 6 months: 57.8% vs 59.4%; P=1.0; - % of participants achieving BCVA >20/40 (Snellen equivalent) at 6 months: 68.4% vs 62.2%; Anatomic outcomes:; - CRT, mean change at 6 months: -212.7 (SD 234.8) vs -177.1 (SD 204.2); P=.34 | - Unclear ROB; - Non-inferiority trial

Abbreviations: BCVA = best-corrected visual acuity; BRVO = branch retinal vein occlusion; CI = confidence interval; CRT = central retinal thickness; CRVO = central retinal vein occlusion; ETDRS = Early Treatment Diabetic Retinopathy Study; logMAR = Logarithm of the Minimal Angle of Resolution chart; OCT = optical coherence tomography; QOL = quality of life; PRN = pro re nata (“as needed”); ROB = risk of bias; RVO = retinal vein occlusion; SD = standard deviation; VEGF = vascular endothelial growth factor.

a Includes 9 patients who were not randomized but rather assigned to bevacizumab for financial reasons.

##### Bevacizumab versus Ranibizumab

Visual Outcomes. Although both groups reported large gains in mean BCVA after 6 months of treatment, neither study reported a significant difference between drugs, and a meta-analysis combining the studies also found no difference (pooled mean difference -1.204 letters [95% CI -5.714 to 3.306], P = .601; Figure 8). Subgroup analyses from one of the trials also found no differences between the drugs in either the BRVO (P = .15) or CRVO (P = .73) subsets. Similarly, the treatment groups did not differ in proportion of participants gaining 15 or more letters from baseline (RR 0.992 [95% CI, 0.805 to 1.223], P = .940; Figure 9). The MARVEL study reported that 68.4% in the bevacizumab group and 62.2% of the ranibizumab group achieved a Snellen equivalent of > 20/40 after 6 months of treatment (P-value not reported).

Figure 8 Mean change in BCVA at 6 months in BRVO or CRVO patients treated with bevacizumab vs ranibizumab

Figure 9 Likelihood of gaining 15 or more letters at 6 months in BRVO or CRVO patients treated with bevacizumab vs ranibizumab

Anatomic Outcomes. Both trials reported no significant differences between drugs in mean reduction in central retinal or foveal thickness. CRAVE reported that most participants in both groups had no intraretinal or subretinal fluid present on OCT images (56.3% in the bevacizumab group vs 51.4% in the ranibizumab group; P = .81).

## KEY QUESTION 2 What are the comparative harms of anti-VEGF agents for retinal/choroidal neovascularization and/or macular edema in adults?

### Overview of Results

Of the 16 trials comparing anti-VEGF agents in our populations of interest, all but 4 reported detailed information about adverse events (Table 5).^26,30,32,33^ Most of these studies (9 RCTs) examined adverse events in patients with AMD. Most trials compared bevacizumab to ranibizumab, but the DRCR.net Protocol T trial compared all 3 anti-VEGF agents in patients with DME, and 2 studies (VIEW 1 and VIEW 2) compared aflibercept to ranibizumab for AMD. Adverse events occurring by the longest-term timepoint reported by a study were prioritized over shorter-term timepoints (eg, rates of events over the first 12 months of a 24-month trial are generally not discussed). None of the trials were specifically designed to assess harms and thus were not powered to detect differences in adverse events between drugs.

Table 5 Harms and Costs of Anti-VEGF Agents for Retinal/Choroidal Neovascularization and/or Macular Edema

Trial name; Author, year; - Population; - Number randomized; - Length of follow-up; - Population characteristics: mean age, % male, mean baseline BCVA | Interventions Groups (number per group); - Treatment Schedule | Harms Outcomes^a^ | Cost and Burden Outcomes | Notes; - ROB; - Other notes
Choroidal Neovascularization Secondary to Age-Related Macular Degeneration (AMD)
Biswas 2011^33^; - Choroidal neovascular membrane secondary to AMD; occult CNV 44%; - 120 (104 analyzed); - 18 months; - 63.9 years (SD NR), 48% male, 57.5 letters | Group 1: Bevacizumab 1.25 mg (n=60) Group 2: Ranibizumab 0.50 mg (n=60); - Schedule: Both groups injected monthly for 3 months, then PRN. | Bevacizumab vs Ranibizumab; - Major complications: 0% vs 0%; P=1.0; - Minor complications: 11.1% vs 7.3%; P=NR | Bevacizumab vs Ranibizumab; - Mean number of injections: 4.3 vs 5.6 | - Unclear ROB
BRAMD (Bevacizumab to Ranibizumab in Patients with Exudative Age-Related Macular Degeneration); Schauwvlieghe 2016^45^; - Primary or recurrent sub-or juxtafoveal CNV secondary to AMD; - 332 (327 analyzed); - 12 months; - 78 years (SD 7), 44% male, 60 letters (SD 13) | Group 1: Bevacizumab 1.25 mg (n=166) Group 2: Ranibizumab 0.5 mg (n=166); - Schedule: Both groups injected monthly. | Bevacizumab vs Ranibizumab; - ≥1 serious adverse event: 21.1% vs 22.3%; P=.87; - Number of adverse events: 256 vs 299; P=.48; - Number of serious adverse events: 34 vs 37; P=.87; Systemic Adverse Events:; - Death due to serious adverse event: 0.6% vs 0.6%; P=.6818; - Cardiac disorders: 2.5% vs 3.7%; - Gastrointestinal disorders: 1.2% vs 1.2% | NR | - Low ROB; - Non-inferiority study.
CATT (Comparison of AMD Treatments Trials); Martin 2012^41,42^; - Previously untreated active CNV due to AMD; - 1208^b^ (1105 analyzed at 12 months, 1030 analyzed at 24 months); - 24 months; - 79.2 years (SD 7.5), 38.2% male, 60.6 letters (SD 13.5) | Group 1: Bevacizumab 1.25 mg monthly* (n=286) Group 2: Ranibizumab 0.5 mg monthly* (n=301) Group 3: Bevacizumab 1.25 mg PRN (n=300) Group 4: Ranibizumab 0.5 mg PRN (n=298); - Schedule: Monthly regimens were given an injection every 28 days; PRN regimens were given one initial injection and then only when signs of active neovascularization were present.; *Patients in the monthly groups were re-randomized at 12 months to either continue monthly injections or switch to PRN dosing (study drug not changed). | Bevacizumab vs Ranibizumab^c^ Ocular Adverse Events:; - Endophthalmitis: 1.2% vs 0.7%; P=.38; - Pseudo-endophthalmitis: 0.2% vs 0.2%; P=1.0; Systemic Adverse Events:; - ≥1 serious systemic adverse event: 39.9% vs 31.7%; P=.004; adjusted RR 1.30 (95% CI, 1.07 vs 1.57), P=.009^d^; - All-cause death: 6.1% vs 5.3%; P=.62; - Arterial thrombotic events: 5.0% vs 4.7%: P=.89; ▪ Nonfatal stroke: 1.4% vs 1.3%; P=1.0; ▪ Nonfatal MI: 1.2% vs 1.5%; P=.80; ▪ Vascular death: 2.4% vs 2.0%; P=.70; - Venous thrombotic events: 1.7% vs 0.5%; P=.054; - HTN: 0.7% vs 0.5%; P=.72; - Cardiac disorders: 10.6% vs 7.8%; P=.11; - Gastrointestinal disorders: 4.8% vs 1.8%; P=.005; - Not previously associated with anti-VEGF treatment (ie, events other than arterial thrombotic events, systemic hemorrhage, congestive heart failure, venous thrombotic events, HTN, and vascular death): 34.5% vs 28.4%; P=.02 | Bevacizumab monthly vs Ranibizumab monthly vs Bevacizumab PRN vs Ranibizumab PRN; - Average cost of drug per patient in US dollars (based on per-dose cost of $50 for compounded bevacizumab and $2,000 for ranibizumab):; ▪ 12 months: 595 vs 23,400 vs 385 vs 13,800; ▪ 24 months: 1,170 vs 44,800 vs 705 vs 25,200; - Mean number of injections :; ▪ 12 months (maximum 13): 11.9 (SD 1.2) vs 11.7 (SD 1.5) vs 7.7 (SD 3.5) vs 6.9 (SD 3.0); P=.003 between PRN groups; ▪ 24 months (maximum 26): 23.4 (SD 2.8) vs 22.4 (SD 3.9) vs 14.1 (SD 7.0) vs 12.6 (SD 6.6); P=.01 between PRN groups | - Low ROB; - Re-randomization: At 12 months, patients initially assigned to monthly treatment retained their drug assignment but were reassigned randomly to either monthly or PRN.
GEFAL (French Study Group Avastin versus Lucentis for Neovascular AMD trial); Kodjikian 2013^34^; - Active subfoveal neovascular AMD; - 501 (404 analyzed); - 12 months; - 79.2 years (SD 7.1), 33.7% male, 55.2 letters (SD 14.0) | Group 1: Bevacizumab 1.25 mg (n=255) Group 2: Ranibizumab 0.5 mg (n=246); - Schedule: Both groups injected monthly for 3 months, then PRN. | Bevacizumab vs Ranibizumab; - ≥1 serious adverse event: 12.6% vs 12.1%; P=.8757; - Withdrawals due to adverse events: 2.8% vs 2.9%; Ocular Adverse Events:; - Eye disorders: 0.8% vs 2.1%; P=.2791; - Retinal artery occlusion: 0.4% vs 0%; - Subretinal hematoma: 0.4% vs 0.8%; - Vitreous hemorrhage: 0% vs 0.4%; - Endophthalmitis: 0% vs 0.4%; - Retinal detachment: 0% vs 0%; - Traumatic cataract: 0% vs 0%; Systemic Adverse Events:; - ≥1 serious systemic adverse event: 12.2% vs 10.0%; P=4510; - Death: 0.8% vs 1.3%; P=.6818; - Arterial thrombotic events:; ▪ MI: 0.4% vs 0.4%; P=1.0; ▪ Stroke: 0% vs 0%; P=1.0; - Venous thrombotic events:; ▪ Pulmonary embolism: 0.4% vs 0%; P=1.0; ▪ Phlebitis: 0% vs 0%; P=1.0; - TIA: 0% vs 0%; P=1.0; - Cardiac disorders: 0.8% vs 2.1%; P=.2791; - HTN: 0.4% vs 0.8%; P=.6189; - Gastrointestinal disorders: 1.2% vs 2.1%; P=.4985 | Bevacizumab vs Ranibizumab; - Mean number of injections: 6.8 (SD 2.7) vs 6.5 (SD 2.4); P=.39; - Patients requiring monthly injections: 4.2% vs 1.6%; P=.14 | - Unclear ROB; - Non-inferiority study.
IVAN (Inhibition of VEGF in Age-related choroidal Neovascularisation trial); Chakravarthy 2013^27,37,38^; - Active previously untreated neovascular AMD with neovascular lesion involving the center of the fovea; - 628 (610 analyzed); - 24 months; - 77.7 years (SD 7.4), 40% male, 61.4 letters (SD 15.3) | Group 1: Bevacizumab 1.25 mg monthly or PRN (n=305)^e^ Group 2: Ranibizumab 0.5 mg monthly or PRN (n=323)^e^; - Schedule: All groups received injections monthly for 3 months, then received injections according to their allocation group (monthly or PRN). | Bevacizumab vs Ranibizumab; - ≥1 serious adverse event: 28.3% vs 27.7%; - Withdrawals due to serious adverse events: 1.3% vs 1.9%; Ocular Adverse Events:; - ≥1 ocular adverse event: 2.0% vs 2.5%; - Endophthalmitis: 0% vs 0%; - Retinal detachment: 0% vs 0.3%; - Retinal hemorrhage: 0% vs 0.3%; - Retinal pigment epithelial tear: 0.3% vs 1.0%; - Traumatic cataract: 0.3% vs 0.3%; - Vitreous hemorrhage: 0.3% vs 0%; - RVO: 0% vs 0.3%; - Uveitis: 0.3% vs 0%; - Infection: 0.3% vs 0.0%; Systemic Adverse Events:; - ≥1 serious systemic adverse event: 27.0% vs 25.8%; OR 0.96 (95% CI, 0.66 to 1.39), P=.82; - All-cause death: 5.1% vs 4.8%; OR 0.96 (95% CI, 0.46 to 2.02), P=91; - Any vascular event, heart failure, or all-cause death: 9.5% vs 12.1%; OR 1.36 (95% CI, 0.80 to 2.29), P=.25; - Arterial thrombotic event: 3.4% vs 4.1%; OR 1.24 (95% CI, 0.53 to 2.86); ▪ Nonfatal MI: 1.4% vs 1.3%; ▪ Nonfatal stroke: 1.0% vs 1.9%; ▪ Vascular death: 1.4% vs 1.0%; - Heart failure: 0.7% vs 2.2%; - Arterial thrombotic events or heart failure: 4.1% vs 6.4%; OR 1.69 (95% CI, 0.80 to 3.57), P=.16; - Venous thrombotic events: 1.4% vs 1.0%; - TIA: 0.3% vs 0.3%; - Hospitalized for angina: 1.0% vs 2.2%; - Cardiac disorders: 6.4% vs 6.4%; - Gastrointestinal disorders: 3.0% vs 1.0%; OR 0.31 (95% CI 0.08 to 1.16), P=.06 | Ranibizumab vs Bevacizumab; - Median number of injections: 18 (IQR 11 to 23) vs 19 (IQR 12 to 23) | - Low ROB
LUCAS (Lucentis Compared to Avastin Study); Berg 2015^39,40^; - Previously untreated active neovascular AMD; - 441 (431 analyzed); - 24 months; - 78.3 years (SD 7.9), 32.5% male, 61.0 letters (SD 13.5) | Group 1: Bevacizumab 1.25 mg (n=220)^f^ Group 2: Ranibizumab 0.5 mg (n=221)^f^; - Schedule: “Treat-and-extend” - patients in both groups were injected every 4 weeks until no signs of active AMD were found, at which point the period to the next treatment was extended by 2 weeks at a time, up to a maximum interval of 12 weeks. If examination showed any sign of recurrence, the interval was shortened by 2 weeks at a time, until the disease was considered to be inactive. Interval extension was then restarted, with the maximum final interval being 2 weeks less than the period when the previous recurrence. | Bevacizumab vs Ranibizumab; - Withdrawals due to adverse events: 7.3% vs 4.1%; Ocular Adverse Events:; - Endophthalmitis: 0.5% vs 0%; P=.499; - Pseudo-endophthalmitis: 1.4% vs 0%; P=.123; - Macular hemorrhage: 1.4% vs 0%; P=.123; - Retinal tear: 0.5% vs 0%; P=.499; - Pigment epithelial rupture: 0.5% vs 0%; P=.499; - Acute glaucoma: 0.5% vs 0%; P=.499; Systemic Adverse Events:; - ≥1 serious systemic adverse event: 29.1% vs 30.3%; P=.778; - All-cause death: 6.8% vs 5.9%; P=.687; - Arterial thrombotic events: 4.1% vs 6.3%; P=.289; ▪ Nonfatal MI: 1.4% vs 4.1%; P=.080; ▪ Nonfatal stroke: 1.4% vs 1.8%; P=1.0; ▪ Vascular death: 1.4% vs 0.9%; P=.685; - Venous or other thrombotic event: 0% vs 1.4%; P=.248; - TIA: 1.4% vs 0%; P=.123; - HTN: 0.9% vs 0.9%; P=1.0; - Cardiac disorder: 5.5% vs 8.6%; P=.197; - Gastrointestinal disorder: 3.2% vs 5.0%; P=.341 | Bevacizumab vs Ranibizumab; - Mean number of injections: 18.2 vs 16.0; mean difference 1.2 (95% CI, -3.4 to -1.0), P≤.001; - Average treatment interval in weeks: 6.5 vs 7.6; - % patients receiving injections at treatment interval:; ▪ 4 weeks: 27% vs 20%; P=.002; ▪ 12 weeks: 10% vs 17%; P=.002 | - Low ROB; - Non-inferiority study.
MANTA (Multicenter Anti-VEFG Trial in Austria); Krebs 2013^35^; - Active primary or recurrent subfoveal lesion with CNV secondary to AMD; - 317 (number analyzed unclear); - 12 months; - 77.2 years (SD 8.0), 36.3% male, 56.7 letters (SD 13.3) | Group 1: Bevacizumab 1.25 mg (n=154) Group 2: Ranibizumab 0.5 mg (n=163); - Schedule: Both groups injected monthly for 3 months, then PRN. | Bevacizumab vs Ranibizumab Ocular Adverse Events: 0% vs 0%; P=1.0 Systemic Adverse Events:; - Death: 1.9% vs 1.2%; P=.61; - Vascular disorders:; ▪ Heart attack: 1.9% vs 1.2%; P=.61; ▪ Stroke: 0.6% vs 0.6%; P=.94; ▪ Mesenteric artery occlusion: 0.6% vs 0%; P=.30; - Arrhythmia: 0.6% vs 0.6%; P=.94; - Nervous system disorder: 1.3% vs 0.6%; P=.53; - Infection: 1.9% vs 1.8%; P=.94; - Injury or procedural complication: 1.3% vs 1.8%; P=.70; - Gastrointestinal disorder: 0% vs 0%; P=1.0 | Bevacizumab vs Ranibizumab; - Mean number of re-treatments: 6.1 (SD 2.8) vs 5.8 (SD 2.7); P=.26 | - Unclear ROB; - Non-inferiority study.
Scholler 2014^29^; - Active previously untreated neovascular AMD; - 55 (number analyzed unclear); - 12 months; - 80.1 years (SD 6.7), 29.1% male, 58.0 letters (SD 11.7) | Group 1: Bevacizumab 1.25 mg (n=29) Group 2: Ranibizumab 0.5 mg (n=26); - Schedule: Both groups injected monthly for 3 months, then PRN. | Bevacizumab vs Ranibizumab Ocular Adverse Events:; - Subretinal bleeding: 0% vs 7.7%; Systemic Adverse Events:; - TIA: 0% vs 3.8% | Bevacizumab vs Ranibizumab; - Mean number of injections: 5.80 (SD 2.28) vs 5.00 (SD 1.67); P=.084 | - High ROB
Subramanian 2010^26^; - Symptomatic CNV affecting the foveal center; 18% classic or predominantly classic CNV; - 28 (22 analyzed); - 12 months; - 78.6 years, 95% male, 34.2 letters | Group 1: Bevacizumab (dose NR; n=20) Group 2: Ranibizumab (dose NR; n=8); - Schedule: Both groups injected monthly for 3 months, then PRN. | - No major ocular or systemic adverse events reported in any subjects who completed the 1-year follow-up visit (no data for patients not completing 1-year visit).; - Minor adverse events (eg, subconjunctival hemorrhage, transient post-injection pain, and elevated IOP) occurred but data was not reported.; - No reports of anterior chamber inflammation, vitreous hemorrhage, retinal detachment, endophthalmitis, or systemic adverse events in patients completing 1-year follow-up. | Bevacizumab vs Ranibizumab; - Mean number of injections: 8 (range 3-8) vs 4 (range 3-6); P=.001 | - High ROB; - VA population
VIEW 1 (VEGF Trap-Eye: Investigation of Efficacy and Safety in Wet AMD Trial 1); Heier 2012^43^; - Active subfoveal CNV lesions or juxtafoveal lesions with leakage affecting the fovea, secondary to AMD.; - 1217 (1210 analyzed); - 12 months (22 month results combined with VIEW 2 and reported separately); - 78 years (SD 8.0), 41.2% male, 55.1 letters (SD 13.1) | Group 1: Aflibercept 2.0 mg monthly (n=304) Group 2: Aflibercept 0.5 mg^g^ monthly (n=304) Group 3: Aflibercept 2.0 mg every other month (after 3 initial monthly doses; n=303) Group 4: Ranibizumab 0.5 mg monthly (n=306); - Schedule: Patients were seen every 4 weeks and given either active treatment or a sham injection depending on randomization group (ie, Group 3 received sham every other visit). | Aflibercept (all groups)^h^ vs Ranibizumab; - Withdrawals due to adverse events: 1.3% vs 1.3%; Ocular Adverse Events:; - ≥1 serious ocular adverse event: 1.8% vs 3.3%; - Endophthalmitis: 0.3% vs 1.0%; - Retinal hemorrhage: 0.2% vs 0.7%; - Posterior capsule opacification: 0% vs 0%; - Increased IOP: 4.5% vs 7.2%; - Treatment-emergent serious retinal detachment: 0.1% vs 0%; - Treatment-emergent serious cataract: 0.1% vs 0%; Systemic Adverse Events:; - ≥1 serious systemic adverse events: 15.5% vs 18.8%; - Arterial thrombotic event: 1.6% vs 1.6%; ▪ Vascular death: 0.5% vs 0.3%; ▪ Nonfatal MI: 0.7% vs 1.3%; ▪ Nonfatal stroke: 0.4% vs 0%; - HTN: 9.0% vs 9.5%; - Venous thrombotic events: 0.1% vs 0.3%; - Congestive heart failure: 0.4% vs 0.7%; - Gastrointestinal perforation or fistula: 0% vs 0%; - Non-ocular hemorrhagic event: 0.7% vs 0.3% | NR for 12 months (when monthly or bimonthly dosing schedules was used); 22-month results combined with VIEW 2 | - Low ROB; - Non-inferiority study.
VIEW 2 (VEGF Trap-Eye: Investigation of Efficacy and Safety in Wet AMD Trial 2); Heier 2012^43^; - Active subfoveal CNV lesions or juxtafoveal lesions with leakage affecting the fovea, secondary to AMD.; - 1240 (1202 analyzed); - 12 months (22 month results combined with VIEW 1 and reported separately); - 73.9 years (SD 8.7), 44.5% male, 52.4 letters (SD 13.9) | Group 1: Aflibercept 2.0 mg monthly (n=313) Group 2: Aflibercept 0.5 mg^g^ monthly (n=311) Group 3: Aflibercept 2.0 mg every other month (after 3 initial monthly doses; n=313) Group 4: Ranibizumab 0.5 mg monthly (n=303); - Schedule: Patients were seen every 4 weeks and given either active treatment or a sham injection depending on randomization group (ie, Group 3 received sham every other visit). | Aflibercept (all groups)^h^ vs Ranibizumab; - Withdrawals due to adverse events: 2.5% vs 0.7%; Ocular Adverse Events:; - ≥1 serious ocular adverse event: 2.2% vs 3.1%; - Endophthalmitis: 0% vs 0%; - Retinal hemorrhage: 0.4% vs 0.3%; - Posterior capsule opacification: 0% vs 0.7%; - Increased IOP: 5.9% vs 6.5%; - Treatment-emergent serious retinal detachment: 0.2% vs 0.3%; - Treatment-emergent serious cataract: 0.2% vs 0.3%; Systemic Adverse Events:; - ≥1 serious systemic adverse events: 12.2% vs 8.9%; - Arterial thrombotic event: 1.9% vs 1.7%; ▪ Vascular death: 0.4% vs 0.3%; ▪ Nonfatal MI: 1.0% vs 0.7%; ▪ Nonfatal stroke: 0.4% vs 0.7%; - HTN: 8.8% vs 10.0%; - Venous thrombotic events: 0% vs 0%; - Congestive heart failure: 0.1% vs 0.3%; - Gastrointestinal perforation or fistula: 0.2% vs 0%; - Non-ocular hemorrhagic event: 0.3% vs 0% | NR for 12 months (when monthly or bimonthly dosing schedules was used); 22-month results combined with VIEW 1 | - Low ROB; - Non-inferiority study.
VIEW 1 and VIEW 2 combined 22-month results; Schmidt-Erfurth 2014^44^; - Active subfoveal CNV lesions or juxtafoveal lesions with leakage affecting the fovea, secondary to AMD; - 2457 (2412 analyzed); - 22 months (96 weeks); - 75.9 years (SD 8.6), 42.8% male, 53.8 letters (SD 13.6) | Group 1: Aflibercept 2.0 mg monthly for 12 months, capped PRN months 12-22 (n=617) Group 2: Aflibercept 0.5 mg^g^ monthly for 12 months, capped PRN months 12-22 (n=615) Group 3: Aflibercept 2.0 mg every other month (after 3 initial monthly doses) for 12 months, capped PRN months 12-22 (n=616) Group 4: Ranibizumab 0.5 mg monthly for 12 months, capped PRN months 12-22 (n=609); - Schedule: During follow-up period from 12 to 22 weeks, patients continued to receive the same dose of study drugs as in the first 12 months, but received injections at least every 12 weeks (capped PRN). | Aflibercept (all groups)^h^ vs Ranibizumab; - Withdrawals due to adverse events: 4.1% vs 2.6%; Ocular Adverse Events:; - ≥1 serious ocular adverse event: 3.6% vs 4.4%; - Serious ocular injection-related adverse event rate (per 1000 injections) at 12 months: 0.3 vs 0.8; - Endophthalmitis: 0.3% vs 0.8%; - Retinal detachment: 0.2% vs 0.5%; - Retinal hemorrhage: 0.7% vs 0.7%; - Retinal pigment epithelial tear: 0.2% vs 0.2%; - Cataract: 0.6% vs 0.2%; - Increased IOP: 1.6% vs 0.2%; - Any intraocular inflammatory response: 0.8% vs 1.5%; - Posterior capsule opacification: 0% vs 0.3%; Systemic Adverse Events:; - ≥1 serious systemic adverse event: 24.0% vs 24.5%; - Arterial thrombotic events: 3.3% vs 3.2%; ▪ Nonfatal MI: 1.4% vs 2.0%; ▪ Nonfatal stroke: 0.7% vs 0.8%; ▪ Vascular death: 1.3% vs 0.5%; - Congestive cardiac failure: 0.9% vs 0.8%; - Coronary artery disease: 0.4% vs 0.8%; - Atrial fibrillation: 1.3% vs 0.8%; - TIA: 0.9% vs 0.2%; - Cerebrovascular accident: 0.8% vs 0.7%; - Death: 2.8% vs 2.7% | Aflibercept 2 mg monthly vs Aflibercept 0.5 mg monthly vs Aflibercept 2 mg bimonthly vs Ranibizumab 0.5 mg monthly; - Mean number of injections at week 96: 16.0 (SD 3.2) vs 16.2 (SD 4.0) vs 11.2 (SD 2.9) vs 16.5 (SD 2.7); - Mean number of injections from months 12-22 (PRN schedule): 4.1 (SD 1.8) vs 4.6 (SD 2.2) vs 4.2 (SD 1.7) vs 4.7 (SD 2.2); P<.0001 aflibercept 2.0mg monthly then PRN vs ranibizumab monthly then PRN; P<.0001 for aflibercept 2.0mg every other month then PRN vs ranibizumab monthly then PRN | - Low ROB for both VIEW 1 and VIEW 2
Diabetic Macular Edema (DME)
DRCR.net (Diabetic Retinopathy Clinical Research Network) Protocol T; Wells 2016^46-48^; - DME involving the macular center; - 660 (578 analyzed at 24 months); - 24 months; - 60.6 years (SD 10), 54% male, 64.8 letters (SD 11.3) | Group 1: Aflibercept 2.0 mg PRN (n=224) Group 2: Bevacizumab 1.25 mg PRN (n=218) Group 3: Ranibizumab 0.3 mg PRN (n=218); - Schedule: All groups injected every 4 weeks unless visual acuity was 20/20 or better, CST was below the eligibility threshold, and no improvement or worsening observed in response to 2 consecutive injections.; - Patients also received focal/grid laser photocoagulation starting at 6-months if DME persisted. | Aflibercept vs Bevacizumab vs Ranibizumab Ocular Adverse Events:; - Endophthalmitis: 0% vs 0.5% vs 0%; P=.66; - Inflammation: 2.7% vs 1.4% vs 1.8%; P=.69; - Retinal detachment (traction, rhegmatogenous, or unspecified): 0.9% vs 0.9% vs 0.9%; P=1.0; - Retinal tear: 0.4% vs 0.5% vs 0.5%; P=1.0; - Vitreous hemorrhage: 6.7% vs 7.8% vs 4.6%; P=37; - Injection-related cataract: 1.3% vs 0.9% vs 0%; P=.38; - Increased IOP: 17.4% vs 12.4% vs 16.5%; P=.31; Systemic Adverse Events:; - ≥1 serious systemic adverse event: 39.3% vs 37.2% vs 37.6%; P=.90; - Arterial thrombotic events: 5.4% vs 7.8% vs 11.9%; global P=.09 (aflibercept vs ranibizumab P=.047); ▪ Nonfatal MI: 3.1% vs 1.4% vs 2.8%; ▪ Nonfatal stroke: 0.9% vs 2.8% vs 5.0%; ▪ Vascular death (from any potential vascular or unknown cause): 1.3% vs 3.7% vs 4.1%; - Death: 2.2% vs 6.0% vs 5.0%; P=. 12; - Hospitalization: 34.4% vs 32.6% vs 33.5%; P=.93; - Gastrointestinal disorders: 29.9% vs 29.4% vs 27.5%; P=.85; - Renal and urinary disorder events: 22.3% vs 21.1% vs 16.1%; P=.22; - HTN: 17.4% vs 12.4% vs 20.2%; P=.08 | Aflibercept vs Bevacizumab vs Ranibizumab; - Total mean costs during one year:^i^ $26,100 vs $4,100 vs $18,600; - Incremental cost-effectiveness ratio over 10 years (model): $349,000 vs reference vs $603,000 per QALY; ▪ Subgroup with lower baseline BCVA (<69 ETDRS letters): $287,000 vs reference vs $817,000 per QALY^j^; - Mean number of injections:; ▪ 12 months: 9.2 (SD 2.0) vs 9.7 (SD 2.3) vs 9.4 (SD 2.1); P-value not reported for mean, but for median number of injections P=.045 for aflibercept vs bevacizumab (P=NS for other comparisons); ▪ 24 months (completers only): 14.2 (SD 4.6) vs 15.3 (SD 5.3) vs 14.8 (SD 5.0); P-value not reported for mean, but for median number of injections P=.08 for overall comparison; - Laser photocoagulation performed at least once:; ▪ 12 months: 37% vs 56% vs 46%; P<.001; ▪ 24 months: 41% vs 64% vs 52%; P<.001 aflibercept vs bevacizumab, P=.04 aflibercept vs ranibizumab, and P=.01 ranibizumab vs bevacizumab | - Low ROB
Ekinci 2014^30^; - Clinically significant DME; - 100 (85 analyzed); - 12 months; - 66.5 years (SD 11.5), 36% male, 0.23 Snellen chart letters (SD 0.12) | Group 1: Bevacizumab 1.25 mg (n=50) Group 2: Ranibizumab 0.05 mg^j^ (n=50); - Schedule: Both groups injected monthly for 3 months, then PRN. Additional monthly doses were administered if CMT was >275 μm or if BCVA increased by ≥3 letters compared with baseline. | - Patients with acute ocular infection (endophthalmitis after intravitreal injection, n=3), stroke, MI (n=2), uncontrolled HTN (n=4), renal failure (n=1) and cataract formation during follow-up period (n=4) were excluded from the study. These events were not reported by group. | Bevacizumab vs Ranibizumab; - Mean number of injections: 5.1 (SD 0.74) vs 6.5 (SD 0.85); P<.05 | - High ROB; - The study excluded patients with certain adverse events during follow-up (acute ocular infection, stroke, MI, uncontrolled HTN, pregnancy, renal failure, and cataract formation).
Nepomuceno 2013^31^; - DME with central involvement; - 63 eyes in 48 patients (60 eyes in 45 patients analyzed)^k^; - 11 months (48 weeks); - 63.8 years (SE 8.9), 45% male, 0.62 logMAR (SE 0.06) | Group 1: Bevacizumab 1.5 mg^l^ PRN (n=32 eyes) Group 2: Ranibizumab 0.5 mg PRN (n=28 eyes); - Schedule: Both groups received injection monthly if CST was 275 μm. | Bevacizumab vs Ranibizumab (percentages based on number of eyes) Ocular Adverse Events:; - Clinically significant cataract progression: 3% vs 0%; - Transient vitreous hemorrhage after acute posterior vitreous detachment: 3% vs 0%; - Endophthalmitis: 0% vs 7%; Systemic Adverse Events:; - Increased blood pressure: 0% vs 4%; - Transient worsening of renal function: 1 patient receiving both treatments; - No patient experienced MI, stroke, or gastrointestinal bleeding throughout the study period. | Bevacizumab vs Ranibizumab; - Mean number of injections: 9.84 (SEM 0.55) vs 7.67 (SEM 0.60); P=.005; - Eyes meeting rescue therapy criteria (85% received additional anti-VEGF injections, and 15% received rescue laser therapy): 28% vs 14%; P=.042 | - High ROB
Macular Edema due to Central Retinal Vein Occlusion (CRVO) or Branch Retinal Vein Occlusion (BRVO)
CRAVE (Comparison of Anti-VEGF Agents in the Treatment of Macular Edema from Retinal Vein Occlusion Trial); Rajagopal 2015^32^; - Macular edema secondary to RVO (60% of patients with BRVO or hemi-RVO, 40% with CRVO); - 102^m^ (98 analyzed); - 6 months; - 71.5 years (SD 12), 44.9% female, 0.745 logMAR (SD 0.42) | Group 1: Bevacizumab 1.25 mg monthly (n=51)^n^ Group 2: Ranibizumab 0.5 mg monthly (n=51); - Schedule: Both groups received monthly injections for 6 months. | Ocular Adverse Events: “No instances of ophthalmic serious adverse events including endophthalmitis, noninfectious uveitis, retinal detachment, retinal tear, or traumatic cataract were encountered. Injection site pain and irritation were the most adverse events.” Systemic Adverse Events: “One patient died from complications of pneumonia. No patients suffered MI or cerebrovascular accident during the study.” | NR | - High ROB
MARVEL; Narayanan 2015^36^; - Center-involving macular edema due to BRVO; - 75 (75 analyzed); - 6 months; - 51.7 years (SD 8.6), 54.6% male, 54.4 letters (SD 12.2) | Group 1: Bevacizumab 1.25 mg PRN (n=38) Group 2 Ranibizumab 0.5 mg PRN (n=37); - Schedule: Both groups injected at baseline then PRN. | Bevacizumab vs Ranibizumab Ocular Adverse Events:; - Endophthalmitis: 0% vs 0%; - Progression of cataract: 7.9% vs 5.4%; - Increased IOP: 2.6% vs 0%; - Developed a BRVO in the fellow eye: 0% vs 2.7%; - Epiretinal membrane: 7.9% vs 0%; Systemic Adverse Events:; - Systemic arterial HTN: 5.3% vs 8.1%; - Hospitalization (for fractured foot and fever): 0% vs 5.4% | Bevacizumab vs Ranibizumab; - Mean number of injections: 3.0 (SD 1.4) vs 3.2 (SD 1.5); - Received rescue grid laser photocoagulation: 21.0% vs 10.8%; P=.34; - Received sector laser photocoagulation due to the development of neovascularization in the retina: 2.6% vs 5.4% | - Unclear ROB; - Non-inferiority trial

Abbreviations: AMD = age-related macular degeneration; BCVA = best-corrected visual acuity; BRVO = branch retinal vein occlusion; CI = confidence interval; CMT = central macular thickness; CNV = choroidal neovascularization; CRVO = central retinal vein occlusion; CST = central subfield thickness; DME = diabetic macular edema; ETDRS = Early Treatment Diabetic Retinopathy Study; IQR = interquartile range; logMAR = Logarithm of the Minimal Angle of Resolution chart; MI = myocardial infarction; NR = not reported; OR = odds ratio; PRN = pro re nata (“as needed”); QALY = quality-adjusted life-year; ROB = risk of bias; RR = relative risk; RVO = retinal vein occlusion; SD = standard deviation; SE = standard error; TIA = transient ischemic attack; VEGF = vascular endothelial growth factor.

a Ocular adverse events are reported for the study eyes only.

b The trial randomized 1208 patients, but 23 patients at one study center were later excluded because of serious protocol noncompliance.^41-42^

c Monthly and PRN groups for each drug were combined. Adverse events within the first 12 months were reported by drug as well as by treatment schedule (monthly or PRN) in the 12-month publication.^41^

d RR for patients treated PRN compared to monthly: 1.20 (95% CI, 0.98 to 1.47), P=.08.

e Results were reported both by drug and treatment schedule; however, as our key questions were not looking at effectiveness according to dosing schedule, only drug comparisons are reported here.

f Patients who developed neovascular AMD in the non-study eye received the same drug in both eyes; 31 patients in the bevacizumab group and 25 patients in the ranibizumab group were treated in both eyes.

g The recommended dose is 2.0 mg.

h Adverse events by individual treatment group are reported in the main publication.^43^

i Included study eye and non-study eye anti-VEGF injections (per-dose cost $1,850 for aflibercept, $1,170 for ranibizumab, and $60 for compounded bevacizumab), laser photocoagulation, and adverse events.

j Ranibizumab 0.05 mg is the dose reported in the published study (potentially an error); the recommended dose is 0.3 mg for patients with DME.

k If both eyes were eligible for treatment and the patient agreed to treat both eyes with anti-VEGF therapy, 1 eye received the randomized treatment according to a computer-generated sequence and the contralateral eye received the other anti-VEGF agent on the next day.

l The recommended dose is 1.25 mg.

m Includes 9 patients who were not randomized but were assigned to bevacizumab for financial reasons.

Rates of serious ocular adverse events were very low in all trials, and none of the studies reported a significant difference between drugs in any ocular adverse event. The strength of evidence was low to moderate for trials of AMD and DME patients (depending on the drug comparison; see Table 6), and insufficient for RVO trials due to the paucity of studies, small sample sizes, and short duration follow-up. Endophthalmitis occurred in less than 1.5% of all groups in every trial except for 2 small DME studies, which both reported rates of approximately 3% for all patients receiving anti-VEGF injections (one study did not report events by treatment arm, and the other study found endophthalmitis in the ranibizumab arm only but did not report statistical comparisons between arms).^30,31^ Rates of other serious ocular adverse events were also low but varied somewhat between trials. The incidence of vitreous hemorrhage was reported in 4 trials and ranged from 0% to 8% of patients (median 0.4%), with the highest rates occurring in the DRCR.net Protocol T trial of DME patients. Retinal detachment occurred in < 1% per group in the 7 studies reporting this outcome, and retinal tear occurred in ≤ 0.5% per group in 5 trials. Treatment-related cataracts occurred in 0% to 1.3% of patients per group in 6 trials (median 0.2%). Elevated intraocular pressure was the most commonly reported ocular adverse event, with a median of 5.9% per group in the 5 trials reporting this outcome, although as high as 17.4% of DME patients in the DRCR.net Protocol T trial experienced increased intraocular pressure during the 24-month trial.

As expected in populations with AMD, DME, and RVO, systemic adverse events were relatively common, although it is unclear how many were caused by intravitreal anti-VEGF treatment. Most trials found no differences between treatment groups, and the strength of evidence was low to moderate for AMD and DME and insufficient for RVO. Rates of patients experiencing at least one serious systemic adverse event ranged from 10% to 40% per treatment group. Rates of arterial thrombotic events as defined by the Anti-Platelet Trialists' Collaboration (vascular death, nonfatal myocardial infarction, or nonfatal stroke) was slightly higher in the DRCR.net trial of DME patients (8.4% total) than in the 7 trials reporting these events in patients with AMD (all groups < 5%). Likewise, hypertension and gastrointestinal disorders were also more common in the DRCR.net trial than in the AMD trials.

### Detailed Results

#### Choroidal Neovascularization Secondary to Age-Related Macular Degeneration (AMD)

Of the 11 trials conducted in patients with AMD, all but 3 (one with unclear ROB^33^ and 2 with high ROB^26,29^) reported detailed ocular and systemic adverse events by treatment arm (6 studies with low ROB and 2 studies with unclear ROB). Nine trials compared bevacizumab to ranibizumab and 2 trials compared aflibercept to ranibizumab. Five of these trials reported statistical comparisons between drugs (all bevacizumab versus ranibizumab).^27,34,35,37-39,41,42^

Patients with one or more serious ocular or systemic adverse events varied in the 3 trials reporting this outcome (11% to 21.7% at 12 months; 28% at 24 months in the IVAN trial), but there were no differences between the groups treated with bevacizumab compared to ranibizumab.^27,34,37,38,45^ Withdrawals due to adverse events were reported in 5 trials and tended to be low in all groups (<1% to 4.5%; P-value between groups not reported in all studies).^27,34,37-39,43,44^ The highest rate of withdrawals due to adverse events occurred in the LUCAS trial, with 4.5% in the bevacizumab group and 2.7% in the ranibizumab group (P-value between groups not reported).

##### Ocular Adverse Events

Reporting and specific rates of ocular adverse events varied between the studies, but were generally low. In the IVAN trial, 2.0% of patients treated with bevacizumab and 2.5% of patients treated with ranibizumab experienced at least one ocular adverse event during the 24-month treatment period (P-value between groups not reported). Combined 22-month results of VIEW 1 and VIEW 2 reported a slightly higher incidence of patients with one or more serious ocular adverse events, with 3.6% in the aflibercept arm and 4.4% in the ranibizumab arm (P-value between groups not reported).

Endophthalmitis occurred in less than 1% of patients in the 5 trials reporting this outcome.^27,34,37-39,43^ The CATT trial reported a slightly higher rate, with 1.2% of the bevacizumab group and 0.7% in the ranibizumab group developing endophthalmitis during the 24-month trial (P = .38).^41,42^ Of note, in the 12-month results, all incidents of endophthalmitis occurred in the groups receiving monthly injections.^41^ Other serious ocular adverse events—such as retinal detachment, retinal or vitreous hemorrhage, retinal tears, and traumatic or treatment-emergent cataracts—were very rare, generally occurring in less than 1% of each group in the 5 large trials reporting these outcomes.^27,34,37-40,43,44^

##### Systemic Adverse Events

The proportion of patients with one or more serious systemic adverse events varied widely between the trials, ranging from 10% (in GEFAL, which did not enroll patients with uncontrolled hypertension despite medical treatment)^34^ to 40%. Of the 6 studies reporting this outcome, the CATT trial reported the highest rates of serious systemic adverse events and was the only trial to find a significant difference between groups. The trial reported 39.9% of patients in the intravitreal bevacizumab arm and 31.7% in the intravitreal ranibizumab arm experienced at least one serious systemic adverse event by the 24-month follow-up visit (P = .004), and thus bevacizumab had an adjusted relative risk of 1.30 (95% CI, 1.07 to 1.57; P = .009; no difference found between groups receiving monthly compared to PRN injections).^41,42^ However, many of the serious adverse events reported in the group taking intravitreal bevacizumab were not events that have been associated with systemic anti-VEGF treatment in previous (cancer) trials^49^ (ie, events other than arterial thrombotic events, venous thrombotic events, systemic hemorrhage, hypertension, and vascular death, which are affected by the VEGF pathway), and thus the meaning of this finding is unclear. The other 5 trials reported similar rates between groups.^27,34,37-40,43,44^

Arterial thrombotic events occurred in up to 5% of patients in the trials reporting this outcome, and rates were very similar between treatment arms for most trials. The LUCAS trial reported a higher rate of arterial thrombotic events in the ranibizumab group at 12 months (4.5% vs 1.4% in bevacizumab group, P = .050), mostly because of an increased rate of nonfatal myocardial infarction; however, this difference disappeared by 24 months (P = .289).^39^ No trial reported significant differences between treatment arms in rates of vascular deaths. Interestingly, the combined results of VIEW 1 and VIEW 2 found that the highest rates of arterial thrombotic events occurred in the groups with the lowest anti-VEGF exposure (3.6% at 22 months in the arm receiving 2 mg of aflibercept every 8 weeks, and 3.8% in the arm receiving monthly injections of aflibercept at the lower than typical dose of 0.5 mg), rather than the groups receiving monthly injections at the standard recommended dose (2.4% and 3.2%; P-values between groups not reported).^44^ None of the trials reported significant differences between groups in rates of stroke or hypertension, and only the LUCAS trial found a difference between drugs in rates of nonfatal myocardial infarction, although the difference did not reach statistical significance (1.4% in the bevacizumab group vs 4.1% in the ranibizumab group, P = .080).^39^

No study found a difference between drugs in rates of death (8 RCTs). Two trials reported higher rates of gastrointestinal disorders among patients treated with bevacizumab compared to ranibizumab (IVAN, P = .06; and CATT, P = .005).^27,37,38,41,42^ The 4 other trials reporting this outcome found no difference between the drugs.

#### Diabetic Macular Edema (DME)

Three RCTs (total N=808) evaluated adverse event outcomes in patients with DME.^30,31,46,47^ However, one trial did not report statistical comparisons between groups,^31^ and another trial did not report adverse events by treatment arm;^30^ both of these studies had serious methodological flaws resulting in high ROB ratings.

##### Ocular Adverse Events

The largest trial, DRCR.net Protocol T (N=660, low ROB), found no significant differences between drugs in rates of ocular adverse events.^46,47^ The most common events reported in the trial were elevated intraocular pressure (occurring in 15.3% of participants, P = .31 between groups), and vitreous hemorrhage (6.4% of participants, P = .37 between groups). Endophthalmitis only occurred in a single patient during the 24-month trial (0.5% of bevacizumab group; P = .66 between groups). Two smaller trials had higher rates of endophthalmitis, with one study reporting 2 patients in the ranibizumab group contracting the infection (7%; P-value between groups not reported),^31^ and 3 patients overall in the other trial (3%; results not reported by group).^30^ Similarly, cataract formation occurred in less than 1% in the DRCR.net trial (P = .38 between groups), but was reported in 3% and 4% of the smaller trials (P-value between groups not reported).

##### Systemic Adverse Events

The DRCR.net Protocol T trial reported high rates of serious systemic adverse events (38%; P = .90 between groups), although the definition for this outcome was not reported.^46,47^ The trial found that the arm treated with intravitreal ranibizumab had significantly higher rates of arterial thrombotic events (5.4% aflibercept vs 7.8% bevacizumab vs 11.9% ranibizumab; aflibercept vs ranibizumab P = .047, bevacizumab vs ranibizumab P = .20). The group also had slightly higher rates of hypertension (17.4% vs 12.4% vs 20.2%; P = .08). As expected in a fairly sick diabetic population (median hemoglobin A1c 7.7 [range 6.8 to 9.2]; mean arterial blood pressure 101 mmHg; median body mass index 32.3 kg/m^2^), rates of other systemic adverse events were fairly high, but no differences were reported between groups (death, hospitalization, gastrointestinal disorders, and kidney dysfunction). The 2 smaller trials did not report statistical differences between groups.^30,31^

#### Macular Edema due to Central Retinal Vein Occlusion (CRVO) or Branch Retinal Vein Occlusion (BRVO)

Two trials (one with unclear ROB^36^ and one with high ROB^32^) reported adverse events in patients with BRVO or CRVO (total N=177). However, both studies were relatively small and they did not report statistical comparisons between treatment groups.

##### Ocular Adverse Events

Neither trial reported any patient with endophthalmitis during the 6-month follow-up period. The MARVEL trial reported that 6.7% of all patients experienced cataract progression (P-value between groups not reported), and 7.9% of patients treated with bevacizumab developed an epiretinal membrane (P-value not reported). The CRAVE trial reported no instances of serious ocular adverse events.

##### Systemic Adverse Events

MARVEL reported that 6.7% of patients developed arterial hypertension during the trial (P-value between groups not reported); however, the majority of participants (67%) had hypertension at baseline. No other relevant systemic adverse events were reported.

## KEY QUESTION 3 What is the comparative cost-effectiveness of anti-VEGF agents for retinal/choroidal neovascularization and/or macular edema in adults?

### Overview of Results

Two trials reported comparative costs of anti-VEGF agents in the US: the CATT trial compared ranibizumab and compounded bevacizumab in AMD patients,^41,42^ and DRCR.net Protocol T compared all 3 anti-VEGF drugs in patients with DME.^48^ No trials evaluated the comparative costs when bevacizumab was not compounded (ie, use of the vial for a single patient with the remainder discarded, which is the current method employed by the VHA). However, 13 of the other 16 trials reported the mean or median number of injections per treatment group (including VIEW 1 and VIEW 2, whose results are combined in the 22-month results). Two trials also reported other outcomes that may have cost implications, such as the percentage of patients needing rescue therapy (eg, laser photocoagulation).^36,46,47^ We found no additional observational or modeling studies assessing comparative costs that met inclusion criteria; however, the DRCR.net Protocol T trial also reported a validated mathematical model to project 10-year cost-effectiveness results.^48^ Overall, based on the available data on treatment costs in 2 comparative trials and one long-term cost model, treatment with bevacizumab is associated with considerably lower costs than treatment with the other 2 agents.

### Detailed Results

A large study in patients with AMD (CATT trial) reported the average cost of the anti-VEGF drug per patient, based on a per-dose cost of $50 for compounded bevacizumab and $2,000 for ranibizumab. Based on a mean number of injections administered over the 24-month trial period (23.4 for bevacizumab monthly group, 22.4 for ranibizumab monthly, 14.1 for bevacizumab PRN, and 12.6 for ranibizumab PRN; P = .01 between PRN groups), the average cost per patient receiving monthly injections was $1,170 for bevacizumab compared to $44,800 for ranibizumab; in the PRN groups, the mean cost was $705 for bevacizumab compared to $25,200 for ranibizumab.^41,42^ In other words, ranibizumab treatment was over 35 times more expensive than bevacizumab using PRN dosing and over 38 times more expensive when the drugs were administered monthly. Although the outcome only included the cost of the drug and not other economic considerations such as costs related to clinic visits, rescue treatment, and adverse events, given the dramatic difference in cost between the drugs, it is likely that comparative treatment costs alone give a fair estimate of the total cost differential between the drugs.

In the DRCR.net Protocol T trial of DME patients, total mean costs per participant over one year of treatment—including study eye and non-study eye anti-VEGF injections (based on per-dose wholesale costs of $1,850 for aflibercept, $1,170 for ranibizumab 0.3 mg, and $60 for compounded bevacizumab), laser photocoagulation, and adverse events—were $26,000 (95% CI, $24,400 to 27,700) for aflibercept, $18,600 (95% CI, $17,100 to 20,200) for ranibizumab, and $4,100 (95% CI, $3,000 to 5,200) for bevacizumab (including the cost of drug compounding).^48^ The study also calculated quality-adjusted life-years (QALYs) per group based on visual acuity achieved and reported adverse events at monthly intervals and summed over the first year of the trial. Based on the total costs and QALY calculations, the one-year incremental cost-effectiveness ratios (compared to bevacizumab) were $1,110,000 per QALY for aflibercept and $1,730,000 per QALY for ranibizumab ($648,000 per QALY for aflibercept compared to ranibizumab). A validated model projecting cost-effectiveness compared to bevacizumab over 10 years calculated these ratios to be $349,000 per QALY for aflibercept and $603,000 per QALY for ranibizumab ($203,000 per QALY for aflibercept vs ranibizumab). In the subgroup with lower baseline BCVA (< 69 ETDRS letters), which saw a greater relative advantage with aflibercept treatment in mean change in BCVA, the incremental cost-effectiveness ratio was $287,000 per QALY compared to bevacizumab. All models and sensitivity analyses showed the incremental cost-effectiveness ratios of aflibercept and ranibizumab compared to bevacizumab to be well above the $50,000 to $150,000 per QALY thresholds frequently cited in the cost-effectiveness literature.^48^ Thus the study authors concluded that based on the very high costs needed for modest improvements in quality of life, aflibercept and ranibizumab at their current prices are not cost-effective compared to bevacizumab.

In this trial, eyes were treated with focal/grid laser photocoagulation starting at 6 months if DME persisted and was no longer showing improvement. By 24-months follow-up, approximately half of participants required laser photocoagulation at least once and there were significant differences between groups, with the bevacizumab group requiring the most treatment (64% vs 41% in aflibercept arm vs 52% in ranibizumab arm; P < .05 for all comparisons). Similarly, the MARVEL trial reported higher rates of rescue macular grid laser photocoagulation among the bevacizumab group (21.0% vs 10.8% for ranibizumab), although the difference was not significant (P = .34).

Because treatment schedules and PRN retreatment criteria differed among the studies, there was a wide range in the mean number of injections reported by the studies, ranging from 2.9 to 10.7 injections per 12 months of treatment (median among trials with PRN treatment schedules, calculated as per 12 months: 7.5 for aflibercept, 6.8 for bevacizumab, and 6.4 for ranibizumab). Of the 8 studies reporting statistical significance calculations between bevacizumab and ranibizumab, 4 trials found that significantly more injections were administered in the bevacizumab group,^26,31,39,41,42^ while one trial found the opposite;^30^ the other 3 trials reported no significant differences between groups.^29,34,35^ The VIEW 1 and VIEW 2 combined results reported fewer injections during the “capped PRN” phase (months 12 to 22) in the aflibercept group than in the ranibizumab group (4.7 vs 4.1, P < .0001).^44^ DRCR.net results comparing all 3 drugs at 24 months also reported fewer aflibercept injections (14.2 vs 15.3 for bevacizumab and 14.8 for ranibizumab), but statistical comparisons between the drugs were not reported.^46-48^