# REFERENCES

1 Department of Veterans Affairs. Visual Impairment and Blindness. 2002; http://www.publichealth.va.gov/docs/vhi/visual_impairment.pdf. Accessed December 28, 2016.
2 U.S. Department of Veterans Affairs. Center for the Prevention and Treatment of Visual Loss. November 15.
3 Klein R, Klein BEK, Moss SE, Davis MD, DeMets DL. The Wisconsin Epidemiologic Study of Diabetic Retinopathy: IV. Diabetic Macular Edema. Ophthalmology. 1984;91(12):1464-1474.6521986
4 Rosenfeld P. A Prescription for Savings: Reducing Drug Costs to Medicare Testimony before the Senate Special Committee on Aging. 2011; http://www.aging.senate.gov/imo/media/doc/hr236pr.pdf. Accessed December 28, 2016.
5 Hutton D, Newman-Casey P, Tavag M, Zacks D, Stein J. Switching to less expensive blindness drug could save medicare part B $18 billion over a ten-year period. Health Aff. (Millwood). 2014;33(6):931-939.24889941
6 Sarwar S, Clearfield E, Soliman M, . Aflibercept for neovascular age-related macular degeneration. Cochrane Database Syst Rev 2016;2:CD011346.
7 Pershing S, Pal Chee C, Asch SM, . Treating age-related macular degeneration: comparing the use of two drugs among Medicare and Veterans Affairs populations. Health Aff. (Millwood). 2015;34(2):229-238.25646102
8 Virgili G, Parravano M, Menchini F, Evans JR. Anti-vascular endothelial growth factor for diabetic macular oedema. Cochrane Database Syst Rev 2014;10:CD007419.
9 Solomon SD, Lindsley K, Vedula SS, Krzystolik MG, Hawkins BS. Anti-vascular endothelial growth factor for neovascular age-related macular degeneration. Cochrane Database Syst Rev 2014;8:CD005139.
10 Wang H, Sun X, Liu K, Xu X. Intravitreal ranibizumab (Lucentis) for the treatment of diabetic macular edema: a systematic review and meta-analysis of randomized clinical control trials. Curr Eye Res. 2012;37(8):661-670.22631452
11 Braithwaite T, Nanji AA, Lindsley K, Greenberg PB. Anti-vascular endothelial growth factor for macular oedema secondary to central retinal vein occlusion. Cochrane Database Syst Rev 2014;5(100909747):CD007325.
12 Browning DJ, Kaiser PK, Rosenfeld PJ, Stewart MW. Aflibercept for age-related macular degeneration: a game-changer or quiet addition? Am. J. Ophthalmol. 2012;154(2):222-226.22813448
13 Eden J, Levit L, Berg A, Morton S, Committee on Standards for Systematic Reviews of Comparative Effectiveness Research, eds. Finding What Works in Health Care: Standards for Systematic Reviews. Washington, DC: Institute of Medicine; 2011.
14 Kansagara D, Faridi A, Bhavsar K, . Comparative clinical and economic effectiveness of anti-vascular endothelial growth factor agents. PROSPERO: CRD42016034076 2016; http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42016034076. Accessed December 28, 2016.
15 Wallace BC, Small K, Brodley CE, Lau J, Trikalinos TA. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the 2nd ACM SIGHIT International Health Informatics Symposium (IHI). 2012:819-824.
16 Treadwell J, Singh S, Talati R, McPheeters M, Reston J. A framework for best evidence approaches can improve the transparency of systematic reviews. J Clin Epidemiol. 2012;65(11):1159-1162.23017634
17 Treadwell J, Singh S, Talati R, McPheeters M, Reston J. A Framework for “Best Evidence” Approaches in Systematic Reviews. 2011; http://www.ncbi.nlm.nih.gov/books/NBK56653/pdf/Bookshelf_NBK56653.pdf. Accessed December 28, 2016.
18 Higgins J, Green S. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. 2011; http://handbook.cochrane.org/. Accessed October 21, 2015.
19 Rosser DA, Cousens SN, Murdoch IE, Fitzke FW, Laidlaw DA. How sensitive to clinical change are ETDRS logMAR visual acuity measurements? Invest Ophthalmol Vis Sci. 2003;44(8):3278-3281.12882770
20 Shah N, Laidlaw DA, Shah SP, Sivasubramaniam S, Bunce C, Cousens S. Computerized repeating and averaging improve the test-retest variability of ETDRS visual acuity measurements: implications for sensitivity and specificity. Invest Ophthalmol Vis Sci. 2011;52(13):9397-9402.22003109
21 Beck RW, Moke PS, Turpin AH, . A computerized method of visual acuity testing: adaptation of the early treatment of diabetic retinopathy study testing protocol. Am. J. Ophthalmol. 2003;135(2):194-205.12566024
22 Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Stat. Med. 1996;15(6):619-629.8731004
23 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-560.12958120
24 Berkman N, Lohr K, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. 2013; http://www.effectivehealthcare.ahrq.gov/ehc/products/457/1752/methods-guidance-grading-evidence-131118.pdf. Accessed December 28, 2016.
25 Atkins D, Chang S, Gartlehner G, . Assessing the Applicability of Studies When Comparing Medical Interventions. 2011; http://www.effectivehealthcare.ahrq.gov/ehc/products/272/603/Methods%20Guide--Atkins--01-03-2011KM.pdf. Accessed December 28, 2016.
26 Subramanian ML, Abedi G, Ness S, . Bevacizumab vs ranibizumab for age-related macular degeneration: 1-year outcomes of a prospective, double-masked randomised clinical trial. Eye (Lond.). 2010;24(11):1708-1715.20885427
27 IVAN Study Investigators, Chakravarthy U, Harding SP, et al. Ranibizumab versus bevacizumab to treat neovascular age-related macular degeneration: one-year findings from the IVAN randomized trial. Ophthalmology. 2012;119(7):1399-1411.22578446
28 Colenbrander A, International Council of Ophthalmology. Visual Standards: Aspects and Ranges of Vision Loss (with Emphasis on Population Surveys). 2002; http://www.icoph.org/downloads/visualstandardsreport.pdf. Accessed December 28, 2016.
29 Scholler A, Richter-Mueksch S, Weingessel B, Vecsei-Marlovits P-V Differences of frequency in administration of ranibizumab and bevacizumab in patients with neovascular AMD. Wien Klin Wochenschr. 2014;126(11-12):355-359.24696051
30 Ekinci M, Ceylan E, Çakici Ö, Tanyildiz B, Olcaysu O, Çaǧatay HH. Treatment of macular edema in diabetic retinopathy: comparison of the efficacy of intravitreal bevacizumab and ranibizumab injections. Expert Rev Ophthalmol. 2014;9(2):139-143.
31 Nepomuceno AB, Takaki E, Paes de Almeida FP, . A prospective randomized trial of intravitreal bevacizumab versus ranibizumab for the management of diabetic macular edema. Am J Ophthalmol. 2013;156(3):502-510.e502.23795985
32 Rajagopal R, Shah GK, Blinder KJ, . Bevacizumab versus ranibizumab in the treatment of macular edema due to retinal vein occlusion: 6-month results of the CRAVE study. Ophthalmic Surg Lasers Imaging Retina. 2015;46(8):844-850.26431300
33 Biswas P, Sengupta S, Choudhary R, Home S, Paul A, Sinha S Comparative role of intravitreal ranibizumab versus bevacizumab in choroidal neovascular membrane in age-related macular degeneration. Indian J. Ophthalmol. 2011;59(3):191-196.21586838
34 Kodjikian L, Souied EH, Mimoun G, . Ranibizumab versus bevacizumab for neovascular age-related macular degeneration: results from the GEFAL noninferiority randomized trial. Ophthalmology. 2013;120(11):2300-2309.23916488
35 Krebs I, Schmetterer L, Boltz A, . A randomised double-masked trial comparing the visual outcome after treatment with ranibizumab or bevacizumab in patients with neovascular age-related macular degeneration. Br. J. Ophthalmol. 2013;97(3):266-271.23292928
36 Narayanan R, Panchal B, Das T, . A randomised, double-masked, controlled study of the efficacy and safety of intravitreal bevacizumab versus ranibizumab in the treatment of macular oedema due to branch retinal vein occlusion: MARVEL Report No. 1. Br. J. Ophthalmol. 2015;99(7):954-959.25631483
37 Chakravarthy U, Harding SP, Rogers CA, . A randomised controlled trial to assess the clinical effectiveness and cost-effectiveness of alternative treatments to Inhibit VEGF in Age-related choroidal Neovascularisation (IVAN). Health Technol Assess. 2015;19(78):1-298.
38 Chakravarthy U, Harding SP, Rogers CA, . Alternative treatments to inhibit VEGF in age-related choroidal neovascularisation: 2-year findings of the IVAN randomised controlled trial. Lancet. 2013;382(9900):1258-1267.23870813
39 Berg K, Pedersen TR, Sandvik L, Bragadottir R Comparison of ranibizumab and bevacizumab for neovascular age-related macular degeneration according to LUCAS treat-and-extend protocol. Ophthalmology. 2015;122(1):146-152.25227499
40 Berg K, Hadzalic E, Gjertsen I, . Ranibizumab or bevacizumab for neovascular age-related macular degeneration according to the Lucentis Compared to Avastin Study Treat-and-Extend Protocol: two-year results. Ophthalmology. 2016;123(1):51-59.26477842
41 CATT Research Group, Martin DF, Maguire MG, . Ranibizumab and bevacizumab for neovascular age-related macular degeneration. N. Engl. J. Med. 2011;364(20):1897-1908.21526923
42 Comparison of Age-related Macular Degeneration Treatments Trials (CATT) Research Group, Martin DF, Maguire MG, . Ranibizumab and bevacizumab for treatment of neovascular age-related macular degeneration: two-year results. Ophthalmology. 2012;119(7):1388-1398.22555112
43 Heier JS, Brown DM, Chong V, . Intravitreal aflibercept (VEGF trap-eye) in wet age-related macular degeneration. Ophthalmology. 2012;119(12):2537-2548.23084240
44 Schmidt-Erfurth U, Kaiser PK, Korobelnik J-F, . Intravitreal aflibercept injection for neovascular age-related macular degeneration: ninety-six-week results of the VIEW studies. Ophthalmology. 2014;121(1):193-201.24084500
45 Schauwvlieghe AM, Dijkman G, Hooymans JM, . Comparing the effectiveness of bevacizumab to ranibizumab in patients with exudative age-related macular degeneration. The BRAMD Study. PLoS One. 2016;11(5):e0153052.27203434
46 Wells J, Glassman A, Ayala A, . Aflibercept, bevacizumab, or ranibizumab for diabetic macular edema: two-year results from a comparative effectiveness randomized clinical trial. Ophthalmology. 2016;123(6):1351-1359.26935357
47 Diabetic Retinopathy Clinical Research Network, Wells JA, Glassman AR, . Aflibercept, bevacizumab, or ranibizumab for diabetic macular edema. N. Engl. J. Med. 2015;372(13):1193-1203.25692915
48 Ross E, Hutton D, Stein J, . Cost-effectiveness of aflibercept, bevacizumab, and ranibizumab for diabetic macular edema treatment: analysis from the Diabetic Retinopathy Clinical Research Network Comparative Effectiveness Trial. JAMA Ophthalmol. 2016;134(8):888-896.27280850
49 Guan M, Zhou Y-P, Sun J-L, Chen S-C. Adverse events of monoclonal antibodies used for cancer therapy. Biomed Res Int. 2015:428169.26075239
50 Ford JA, Elders A, Shyangdan D, Royle P, Waugh N The relative clinical effectiveness of ranibizumab and bevacizumab in diabetic macular oedema: an indirect comparison in a systematic review. BMJ. 2012;345:e5182.22890029
51 Ford JA, Shyangdan D, Uthman OA, Lois N, Waugh N Drug treatment of macular oedema secondary to central retinal vein occlusion: a network meta-analysis. BMJ Open. 2014;4(7):e005292.
52 Finger RP, Wickremasinghe SS, Baird PN, Guymer RH Predictors of anti-VEGF treatment response in neovascular age-related macular degeneration. Surv. Ophthalmol. 2014;59(1):1-18.24332379
53 Amoaku WM, Chakravarthy U, Gale R, . Defining response to anti-VEGF therapies in neovascular AMD. Eye (Lond.). 2015;29(6):721-731.25882328
54 Abedi F, Wickremasinghe S, Richardson AJ, Islam AFM, Guymer RH, Baird PN Genetic influences on the outcome of anti-vascular endothelial growth factor treatment in neovascular age-related macular degeneration. Ophthalmology. 2013;120(8):1641-1648.23582991
55 Fauser S, Lambrou GN Genetic predictive biomarkers of anti-VEGF treatment response in patients with neovascular age-related macular degeneration. Surv. Ophthalmol. 2015;60(2):138-152.25596882
56 Park UC, Shin JY, McCarthy LC, . Pharmacogenetic associations with long-term response to anti-vascular endothelial growth factor treatment in neovascular AMD patients. Mol. Vis. 2014;20:1680-1694.25558172
57 van Asten F, Rovers MM, Lechanteur YTE, . Predicting non-response to ranibizumab in patients with neovascular age-related macular degeneration. Ophthalmic Epidemiol. 2014;21(6):347-355.25157998
58 Dedania VS, Grob S, Zhang K, Bakri SJ Pharmacogenomics of response to anti-VEGF therapy in exudative age-related macular degeneration. Retina. 2015;35(3):381-391.25635578
59 Sivaprasad S, Dugel PU, Hillenkamp J, . Baseline visual acuity strongly predicts visual acuity gain in patients with diabetic macular edema following anti-VEGF treatment: a cross trial comparison in DME. Ophthalmologica 2014;232:19.
60 Ying GS, Huang J, Maguire MG, . Baseline predictors for one-year visual outcomes with ranibizumab or bevacizumab for neovascular age-related macular degeneration. Ophthalmology. 2013;120(1):122-129.23047002
61 Moja L, Lucenteforte E, Kwag KH, . Systemic safety of bevacizumab versus ranibizumab for neovascular age-related macular degeneration. Cochrane Database Syst Rev 2014;9:CD011230.
62 Thulliez M, Angoulvant D, Le Lez ML, . Cardiovascular events and bleeding risk associated with intravitreal antivascular endothelial growth factor monoclonal antibodies: systematic review and meta-analysis. JAMA ophthalmology. 2014;132(11):1317-1326.25058694
63 U.S. Food and Drug Administration. FDA Alerts Health Care Professionals of Infection Risk from Repackaged Avastin Intravitreal Injections. 2011; http://www.fda.gov/Drugs/DrugSafety/ucm270296.htm. Accessed December 28, 2016.
64 Haddock LJ, Ramsey DJ, Young LH Complications of subspecialty ophthalmic care: endophthalmitis after intravitreal injections of anti-vascular endothelial growth factor medications. Semin. Ophthalmol. 2014;29(5-6):257-262.25325851
65 Fintak DR, Shah GK, Blinder KJ, . Incidence of endophthalmitis related to intravitreal injection of bevacizumab and ranibizumab. Retina. 2008;28(10):1395-1399.18827737
66 Gregori N, Flynn H, Schwartz S, . Current infectious endophthalmitis rates after intravitreal injections of anti-vascular endothelial growth factor agents and outcomes of treatment. Ophthalmic Surg Lasers Imaging Retina. 2015;46(6):643-648.26114845
67 VanderBeek BL, Bonaffini SG, Ma L Association of compounded bevacizumab with postinjection endophthalmitis. JAMA Ophthalmol. Oct 2015;133(10):1159-1164.26270251
68 Carneiro AM, Costa R, Falcao MS, . Vascular endothelial growth factor plasma levels before and after treatment of neovascular age-related macular degeneration with bevacizumab or ranibizumab. Acta Ophthalmol. (Copenh.). 2012;90(1):e25-30.
69 Zehetner C, Kralinger MT, Modi YS, . Systemic levels of vascular endothelial growth factor before and after intravitreal injection of aflibercept or ranibizumab in patients with age-related macular degeneration: a randomised, prospective trial. Acta Ophthalmol. (Copenh.). 2015;93(2):e154-159.
70 Avery RL, Gordon GM Systemic safety of prolonged monthly anti-vascular endothelial growth factor therapy for diabetic macular edema: a systematic review and meta-analysis. JAMA Ophthalmol. 2016;134(1):21-29.26513684
71 American Society of Cataract and Refractive Surgery. Food and Drug Administration (FDA) Issues Draft Guidance on Repackaging of Biologics; Will Permit Compounding Pharmacies and Outsourcing Facilities to Repackage Avastin for Ophthalmic Use. http://www.ascrs.org/node/21402. Accessed December 27, 2016.
72 U.S. Food and Drug Administration. Mixing, Diluting, or Repackaging Biological Products Outside the Scope of an Approved Biologics License Application: Guidance for Industry (Draft Guidance). 2015; http://www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/UCM434176.pdf. Accessed December 28, 2016.
73 Canadian Agency for Drugs and Technologies in Health (CADTH), Thomas SM, Pham B, . Anti-Vascular Endothelial Growth Factor Drugs for Retinal Conditions: A Therapeutic Review. 2015; https://www.cadth.ca/sites/default/files/pdf/TR0009_Anti-VEGF_TR_Science_Report.pdf. Accessed December 28, 2016.
74 Zhu M, Chew JK, Broadhead GK, . Intravitreal Ranibizumab for neovascular Age-related macular degeneration in clinical practice: five-year treatment outcomes. Graefes Arch. Clin. Exp. Ophthalmol. 2015;253(8):1217-1225.25205618
75 Wecker T, Ehlken C, Bühler A, . Five-year visual acuity outcomes and injection patterns in patients with pro-re-nata treatments for AMD, DME, RVO and myopic CNV. Br J Ophthalmol May 23 2016.
76 Comparison of Age-related Macular Degeneration Treatments Trials (CATT) Research Group, Maguire M, Martin D, . Five-year outcomes with anti-vascular endothelial growth factor treatment of neovascular age-related macular degeneration: the Comparison of Age-Related Macular Degeneration Treatments Trials. Ophthalmology. 2016;123(8):1751-1761.27156698