# METHODS

## TOPIC DEVELOPMENT

This topic was nominated by Dr. Glenn Cockerham, National Program Director for VHA Ophthalmology Services. The scope and key questions of this report were determined during a topic refinement process that included a preliminary review of published peer-reviewed literature, discussion with internal partners and investigators, and consultation with content experts and key stakeholders. This review follows established systematic review methodology^13^ and a protocol describing the review plan was posted to the PROSPERO International Prospective Register of Systematic Reviews website before the review was initiated.^14^ The key research questions for this review are as follows:

Key Question 1: What is the comparative clinical effectiveness of anti-VEGF agents for retinal/choroidal neovascularization and/or macular edema in adults?

Key Question 2: What are the comparative harms of anti-VEGF agents for retinal/choroidal neovascularization and/or macular edema in adults?

Key Question 3: What is the comparative cost-effectiveness of anti-VEGF agents for retinal/choroidal neovascularization and/or macular edema in adults?

## SEARCH STRATEGY

Search strategies were developed in consultation with a research librarian (Appendix A). To identify relevant articles, we searched Ovid MEDLINE from database inception to December 11, 2015 and PubMed, Elsevier EMBASE, and Ovid EMB Reviews (CDSR, DARE, HTA, Cochrane CENTRAL, etc) from database inception to February 2, 2016. Grey literature sources included trial registries (ClinicalTrials.gov, International Clinical Trials Registry Platform [WHO ICTRP], and the ISRCTN Registry), regulatory agencies, conference proceedings, and Scientific Information Packet requests for unpublished data from pharmaceutical manufacturers. In addition, the bibliographies of relevant primary studies and recent systematic reviews were reviewed to identify additional eligible studies.

## STUDY SELECTION

Titles and abstracts were reviewed for potential relevance to the Key Questions using the online abstract screening software Abstrackr.^15^ Potentially relevant articles were reviewed at the full-text level using prespecified inclusion/exclusion criteria (Table 1). Two independent reviewers agreed on the final inclusion/exclusion decision for all articles; any disagreements were resolved by consensus or discussion with a third reviewer.

Table 1 PICOTS and Key Questions

Key Question (KQ) | KQ1. What is the comparative clinical effectiveness of anti-VEGF agents for retinal/choroidal neovascularization and/or macular edema in adults? | KQ2. What are the comparative harms of anti-VEGF agents for retinal/choroidal neovascularization and/or macular edema in adults? | KQ3. What is the comparative cost-effectiveness of anti-VEGF agents for retinal/choroidal neovascularization and/or macular edema in adults?
Population | Adults treated with anti-VEGF agents due to one of the following conditions:; - Diabetic macular edema (DME); - Branch retinal vein occlusion (BRVO) or central retinal vein occlusion (CRVO) with cystoid macular edema; - Choroidal neovascularization secondary to age-related macular degeneration (AMD)/neovascular AMD; - Vitreous hemorrhage/proliferative diabetic retinopathy/neovascular glaucoma; [underlined: Excluded:] Uveitic cystoid macular edema; inflammatory choroidal neovascularization; idiopathic choroidal neovascularization.
Intervention | Anti-VEGF injection therapy with one of the following agents:; - Aflibercept (Eylea; Trap-Eye); - Bevacizumab (Avastin); - Ranibizumab (Lucentis)
Comparator | One anti-VEGF intervention versus another anti-VEGF intervention (head-to-head)
Outcomes | - Visual acuity: Mean change in BCVA using the ETDRS chart or other standardized chart; gain or loss of 15 letters/3 lines (or other specified cutoff); percentage of participants reaching pre-specified visual acuity cutoff; - Intermediate outcomes: Change in central macular/subfield thickness using OCT; resolution of subretinal/intraretinal fluid; resolution of neovascularization of the iris, disc, or elsewhere; hemorrhage; - Functional status/Quality of life (eg, NEI VFQ-25); - Other measures of vision (eg, reading ability, reading speed, contrast sensitivity) | - Infection/endophthalmitis; - Retinal detachment; - Glaucoma/elevated intraocular pressure; - Ocular arterial occlusion; - Retinal atrophy; - Injection-related cataract/lens damage; - Systemic adverse events; - Other reported harms | - Cost; - Number of injections needed; - Proportion of patients requiring rescue interventions/co-interventions
Timing | Short- and long-term outcomes
Setting | Outpatient settings | | Cost outcomes from outpatient settings in the US.
Study design | Controlled clinical trials (randomized or non-randomized). [underlined: Excluded:] Observational studies, reviews^*^, opinions, case studies, and case series. ^*^Systematic reviews used to identify eligible trials. | | Systematic reviews, meta-analyses, controlled clinical trials (randomized or non-randomized), cohort studies, and validated modeling studies.

Abbreviations: BCVA = best-corrected visual acuity; ETDRS = Early Treatment of Diabetic Retinopathy Study; KQ = Key Question; NEI VFQ-25 = 25-item National Eye Institute Visual Functioning Questionnaire; OCT = optical coherence tomography; US = United States; VEGF = vascular endothelial growth factor.

The 3 anti-VEGF agents of interest were: aflibercept (Eylea®), bevacizumab (Avastin®), and ranibizumab (Lucentis®). Studies eligible for inclusion compared at least 2 of these agents in adults with retinal or choroidal neovascularization and/or macular edema and reported at least one outcome of interest (visual acuity, intermediate anatomic outcomes from optical coherence tomography [OCT] or other imaging, functional status, quality of life, harms, or cost). We used a best evidence approach to guide our study design inclusion criteria.^16,17^ During an initial scan of the literature, we identified several large controlled trials examining benefits and harms, and therefore we did not include observational studies for Key Questions 1 or 2. On the other hand, we did include cohort and validated modeling studies in addition to trials for Key Question 3 on costs, although we limited these to studies in the US given the marked variability in drug costs across countries.

## DATA ABSTRACTION

Data from included studies were abstracted into a customized database by one reviewer and confirmed by a second reviewer. From each study, we abstracted the following information where available: study objective, population characteristics, main participant inclusion and exclusion criteria, number of subjects, duration of follow-up, study interventions and dosing schedules, important co-interventions, visual acuity outcomes, quality of life/functional status, anatomic outcomes, harms, mean number of injections, costs, and funding source.

## QUALITY ASSESSMENT

Two reviewers independently assessed the quality of each trial using a tool developed by the Cochrane Collaboration (Appendix B),^18^ and disagreements were resolved through discussion. Each trial was given an overall summary assessment of low, unclear, or high risk of bias (ROB).

## DATA SYNTHESIS

We summarized the primary literature by abstracting relevant data and qualitatively synthesizing the literature for each key question. Our primary outcomes of interest were visual acuity and included the proportion of patients experiencing an improvement in BCVA from baseline (represented by a gain of 15 or more ETDRS letters) and overall mean change in BCVA. Based on discussion with our technical experts, we felt a difference of less than 5 ETDRS letters (one line) between treatment groups in mean change in BCVA was not likely to be clinically meaningful or represent an absolute relative improvement that could be perceived by patients (an ETDRS score change of less than 5 letters is also generally not considered to be reliable^19-21^). We also reported intermediate anatomic outcomes such as macular/subfield thickness and absence of retinal/subretinal fluid using OCT imaging. We prioritized long-term outcomes when these were reported (18 and 24 months), but also reported short-term outcomes if longer-term data were not available (6 and 12 months).

We also considered clinical and methodological diversity as well as statistical heterogeneity to determine the appropriateness of performing meta-analyses to estimate the summary effects. Due to relative homogeneity among studies, we conducted meta-analyses using study-level data for the 2 outcomes that were both the most commonly reported and the most clinically meaningful: mean BCVA change from baseline in ETDRS letters (continuous outcome), and participants gaining 15 or more ETDRS letters (dichotomous outcome). We performed analyses according to clinical populations; however, we also conducted exploratory meta-analyses that combined the different disease populations.

Meta-analyses of mean change in BCVA were performed using the differences between treatments in score change from baseline to follow-up. We used the mean difference between arms reported in the study when it was available (if reported, least squares [LS] mean difference was chosen over raw mean difference); otherwise, we calculated mean differences between treatments based on reported data. If necessary, the correlation between the baseline and follow-up was assumed to be 0.5 to calculate the standard deviation for the change score in each group. Sensitivity analyses using alternative assumptions (0.3 and 0.8) produced similar results. We also performed a sensitivity analysis by calculating treatment difference based on follow-up score and the results were very similar. For the dichotomous outcome of participants gaining 15 or more ETDRS letters, we used risk ratios to generate a combined estimate. In all meta-analyses, we used the profile-likelihood random-effects model^22^ while incorporating variation among studies. We assessed the presence of statistical heterogeneity among the studies using the standard Cochran's chi-square test, and the magnitude of heterogeneity using the I^2^ statistic.^23^ All analyses were performed using Stata/IC 13.1 (StataCorp, College Station, TX).

## RATING THE BODY OF EVIDENCE

We assessed the overall strength of evidence for outcomes using a method developed for the Agency for Healthcare Research and Quality's (AHRQ) Evidence-based Practice Centers.^24^ The AHRQ method considers study limitations, directness, consistency, precision, and reporting bias to classify the strength of evidence for individual outcomes independently for randomized controlled trials and observational studies, with supplemental domains of dose-response association, plausible confounding that would decrease the observed effect, and strength of association, as well as separate guidance for applicability.^25^ Ratings were based on the following criteria:

- High = Very confident that the estimate of effect lies close to the true effect for the outcome. The body of evidence has few or no deficiencies, the findings are stable, and another study would not change the conclusions.
- Moderate = Moderately confident that the estimate of effect lies close to the true effect for the outcome. The body of evidence has some deficiencies and the findings are likely to be stable, but some doubt remains.
- Low = Limited confidence that the estimate of effect lies close to the true effect for the outcome. The body of evidence has major or numerous deficiencies (or both). Additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Insufficient = No evidence, unable to estimate an effect, or no confidence in the estimate of effect for the outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

## PEER REVIEW

A draft version of this report was reviewed by 6 individuals with technical expertise and clinical leadership. Their comments and our responses are presented in Appendix C.