# INTRODUCTION

Visual impairment among United States (US) Veterans has risen dramatically over recent decades, and worsening visual acuity is responsible for substantial reductions in quality of life and the ability to perform everyday tasks.^1^ An estimated 1.5 million Veterans currently have vision-threatening diseases,^2^ and as the proportion of elderly Veterans receiving care at the Veterans Health Administration (VHA) continues to grow, vision-related problems will become even more prevalent.

Leading causes of vision loss at the VHA include diseases such as age-related macular degeneration (AMD), diabetic macular edema (DME), and retinal vein occlusion (RVO). AMD is the most common cause of permanent vision loss in elderly populations of developed countries. As the disease progresses to the more severe neovascular (“wet”) type of macular degeneration, abnormal growth of blood vessels in the macula can lead to leakage of fluid, bleeding, and scarring of retinal tissue, which can result in severe visual impairment. While AMD primarily affects older adults, diabetic retinopathy is the most common cause of vision loss in working-age adults, usually as a result of leaking retinal blood vessels causing DME. Nearly one million Veterans have DME,^2^ and if left untreated, it can cause moderate vision loss (best-corrected visual acuity [BCVA] of 55 to 70 letters or loss of 15 letters on the Early Treatment of Diabetic Retinopathy Study [ETDRS] chart) in an estimated 20% of patients after 3 years.^3^ Branch or central retinal vein occlusion (BRVO or CRVO) can also cause macular edema leading to vision loss.

Fortunately, drugs known as anti-vascular endothelial growth factor (anti-VEGF) agents have been developed that target and bind to the factor responsible for this abnormal blood vessel growth and leakage, thus inhibiting its activity. The first such drug designed for ocular administration was ranibizumab (Lucentis® by Genentech), approved by the Food and Drug Administration (FDA) in 2006. Recognizing similarities between this drug and another anti-VEGF agent called bevacizumab (Avastin® by Genentech) initially developed as a cancer treatment, researchers tested its use intravitreally in a large multicenter clinical trial. Results were positive, and since 2005, bevacizumab has been widely used off-label by ophthalmologists to treat patients with AMD, DME, and RVO.^4,5^ Because bevacizumab is not FDA-approved for ocular conditions, it either requires aseptic compounding or one-time use of the large vial packaged for use as chemotherapy—the method currently used by the VHA. A third anti-VEGF agent known as aflibercept (Eylea® by Regeneron-Bayer HealthCare; also referred to as VEGF Trap-Eye) was approved for ocular indications in 2011. Aflibercept's unique binding activity is believed to give it a longer duration of action, and thus the drug could require less frequent injections than bevacizumab or ranibizumab.^6^ Another agent, pegaptanib (Macugen®), was previously used to treat these conditions, but since other more effective agents became available its use virtually vanished (accounting for 1% of anti-VEGF Medicare claims in 2011).^7^

These anti-VEGF agents have been shown to reduce the burden of AMD, DME, and RVO by slowing or even reversing the vision loss typically associated with these diseases. Several systematic reviews have found evidence of a significant benefit with anti-VEGF agents over sham or other therapies.^8-11^ This has led to rapid increases in their use over recent years, with the number of patients being treated with bevacizumab or ranibizumab at the VHA more than doubling from 2008 to 2011.^7^ However, there are substantial cost differences between the drugs, with an estimated cost per dose of $55 for compounded bevacizumab (∼$600 for single use of the commercially available vial), $1,170 or $2,023 for ranibizumab (depending on the indication; recommended dose is 0.3 mg for DME and 0.5 mg for AMD and BRVO/CRVO), and $1,850 for aflibercept.^5,12^ Since patients need regular intravitreal injections in order to maintain vision, it is no surprise that these treatments represent an enormous cost to US healthcare systems. In fact, Medicare Part B spent nearly $2 billion on bevacizumab and ranibizumab in 2010 alone, accounting for one-sixth of its entire budget.^5^ The VHA has a similar patient profile to Medicare, with an aging population and increasing incidence of AMD and diabetes mellitus. However, 2011 data show that the more expensive ranibizumab is used more often within the VHA (52% of patients receiving anti-VEGF drugs compared to 37% of Medicare patients). This is likely due to safety concerns following several VHA patients contracting endophthalmitis in early 2011 and the theoretical risk of increased arterial thrombotic events with bevacizumab treatment, an important concern in the VHA due to the high rate of cardiovascular comorbidities in Veterans.^7^ Thus, it is possible that anti-VEGF drugs constitute an even larger proportion of spending within the VHA.

Despite the widespread use of these drugs and the significant resources spent on them, there is uncertainty about their comparative effectiveness and safety. Therefore, the purpose of this systematic review is to compare the effectiveness, harms, and costs of the 3 anti-VEGF drugs currently used for patients with retinal or choroidal neovascularization and/or macular edema due to diseases such as AMD, DME, and RVO.