# APPENDIX D DETAILED DATA ABSTRACTION

## Abbreviations Used in Appendix D

Abbreviation: Term
AE: Adverse event
AMD: Age-related macular degeneration
B: Bevacizumab
BCVA: Best-corrected visual acuity (represented in ETDRS letters unless otherwise indicated)
BRVO: Branch retinal vein occlusion
CI: Confidence interval
CFT: Central foveal thickness
CMT: Central macular thickness
CNV: Choroidal neovascularization
CRT: Central retinal thickness
CRVO: Central retinal vein occlusion
CST: Central subfield thickness
DME: Diabetic macular edema
EQ-5D: European Quality of Life-5 Dimensions
ETDRS: Early Treatment of Diabetic Retinopathy Study
FA: Fluorescein angiogram
G: Group (G1 = Group 1)
GMR: Geometric mean ratio
HbA1c: Hemoglobin A1c
HR: Hazard ratio
HTN: Hypertension
IOP: Intraocular pressure
IQR: Interquartile range
ITT: Intention-to-treat
logMAR: Logarithm of the Minimal Angle of Resolution
LS: Least squares
MacDQoL: Macular Disease-dependent Quality of Life
MacTSQ: Macular Disease Treatment Satisfaction Questionnaire
MI: Myocardial infarction
N: Number
NCT: National Clinical Trial register number (ClinicalTrial.gov)
NEI VFQ-25: 25-item National Eye Institute Visual Functioning Questionnaire
NR: Not reported
NS: Not significant
OCT: Optical coherence tomography
OR: Odds ratio
PDT: Photodynamic therapy
PRN: Pro re nata (“as needed”)
QOL: Quality of life
R: Ranibizumab
PRP: Panretinal photocoagulation
RR: Relative risk
RVO: Retinal vein occlusion
SD: Standard deviation
SE: Standard error
SEM: Standard error of the mean
TIA: Transient ischemic attack
VEGF: Vascular endothelial growth factor
US: United States

## Trials in Patients with Choroidal Neovascularization Secondary to Age-Related Macular Degeneration (AMD)

Study | Biswas 2011^33^ | BRAMD; Schauwvlieghe 2016^45^ | CATT; Martin 2012^41,42^
- Follow-up; - Country; - NCT or ID number; - Funding | - 18 months; - India; - NR; - None (“Source of Support: Nil.”) | - 12 months; - the Netherlands; - Trialregister.nl NTR1704; - The Netherlands Organisation for Health Research and Development; Dutch health insurance companies | - 24 months; - US; - NCT00593450; - National Eye Institute
Objective | To determine and compare the efficacy and safety of intravitreal ranibizumab and bevacizumab in treatment of choroidal neovascular membrane due to AMD. | To compare the effectiveness of bevacizumab and ranibizumab in the treatment of exudative AMD. | To assess the relative efficacy and safety of ranibizumab and bevacizumab and to determine whether PRN regimen would compromise long-term visual acuity, as compared with a monthly regimen.
Population/Condition | Choroidal neovascular membrane secondary to AMD. | Primary or recurrent sub- or juxtafoveal CNV secondary to AMD. | Previously untreated active CNV due to AMD
Population Characteristics (baseline) | Age: 63.9 years (SD NR) Male: 48% (B vs R: 56% vs 41%) Mean BCVA: 57.5 (B vs R: 56.80 vs 58.19) Mean CMT: 286.2 μm Occult choroidal neovascular membrane: 44% | Age: 78 years (SD 7) Male: 44% Mean BCVA: 60 (SD 13) Mean CRT: 378 μm (SD 115) | Age: 79.2 years (SD 7.5) Male: 38.2% White: 98.6% Mean BCVA: 60.6 (SD 13.5) Mean foveal thickness: 460 μm (SD 187)
Main Inclusion Criteria | Patients aged more than 50 years; patients with baseline BCVA 35-70; all cases of CNV with classic and occult lesions; all cases of subfoveal and juxtafoveal CNV; cases with active leakage pattern; baseline CMT ≥250 μm. | Age ≥60 years; primary or recurrent sub- or juxtafoveal CNV secondary to AMD; total area of CNV of < 12 disc areas; BCVA 20-78 letters. | Age ≥50 years; presence in the study eye (one eye per patient) of previously untreated active CNV due to AMD (leakage on FA and subretinal or intraretinal fluid on OCT); visual acuity 20/25 to 20/320 on electronic visual-acuity testing; CNV or sequela of the CNV involving the center of the fovea.
Main Exclusion Criteria | Previous treatment for CNV in either eye; macular scarification; coexisting other ocular pathology (like advanced cataract, high myopia, chorio-retinal atrophic patches, diabetic retinopathy, glaucoma); one-eyed patients; history of ocular surgery within last 6 months; history of cerebrovascular accident and MI. | The patient was labelled as a poor-responder and treatment was changed to the other drug if at any visit after the third injection there was a drop in BCVA of >10 letters compared to baseline and there was clear evidence of active CNV or leakage by qualitative OCT and/or FA assessment or at least two of the following signs of leakage on OCT: CRT >300 μm, intraretinal cysts or subretinal fluid any time after the third injection. | Previous treatment in the study eye; previous treatment with intravenous bevacizumab or concurrent use of systemic anti-VEGF agents; any concurrent intraocular condition in the study eye (eg, cataract or diabetic retinopathy) that could either require medical or surgical intervention during the 2 year follow-up period; active or recent (within 4 weeks) intraocular inflammation; current vitreous hemorrhage in the study eye.
Intervention vs Comparator; - Schedule; - Co-Intervention/Rescue Treatment | G1: Bevacizumab 1.25 mg G2: Ranibizumab 0.5 mg; - Schedule (both groups): monthly for 3 months; retreatment afterwards based on OCT or BCVA changes (increase in CMT of > 100 μm after the initial 3 injections in or fall in BCVA by >5 letters).; - Full aseptic measures on 3 consecutive months | G1: Bevacizumab 1.25 mg G2: Ranibizumab 0.5 mg; - Schedule (both groups): Administered monthly. | G1: Bevacizumab 1.25 mg monthly G2: Ranibizumab 0.5 mg monthly G3: Bevacizumab 1.25 mg PRN G4: Ranibizumab 0.5 mg PRN; - Schedule: Monthly regimens were given an injection every 28 days; PRN regimens were given one initial injection and then only when signs of active CNV were present (fluid on OCT, new or persistent hemorrhage, decreased visual acuity as compared with the previous examination, or dye leakage or increased lesion size on FA). Patients in the monthly groups were re-randomized at 12 months to either continue with monthly injections or switch to PRN (study drug not changed).; - At the discretion of the investigator, topical antibiotic was used 4 times a day for 3 days (including day of injection).
N | 120 G1: 60 (50 analyzed) G2: 60 (54 analyzed) | 332 (327 analyzed) G1: 166 G2: 166 | 1208 (1105 analyzed at 12 months, 1030 analyzed at 24 months) G1: 286 G2: 301 G3: 300 G4: 298
Visual Outcomes (ETDRS chart unless otherwise indicated); Functional Status/QOL Outcomes | G1 vs G2; - Mean change in BCVA:; - 12 months: 0.52 vs 3.22; P=.463; - 18 months: 3.96 vs 3.56; P=.563; - Mean BCVA achieved:; - 12 months: 57.32 vs 61.41; - 18 months: 60.76 vs 61.74; - Proportion of participants gaining/losing BCVA letters from baseline:; - Gaining >15 letters: 12% vs 26%; - Gaining >5 letters: 32% vs 33%; - Maintaining BCVA (≤5 letters change): 60% vs 56%; - Losing >5 letters: 8% vs 11%; - Losing >15 letters: 0% vs 4% | G1 vs G2; - Mean change in BCVA: 5.1 (SD 14.1) vs 6.4 (12.2); P=.37; - Mean BCVA achieved: 65.0 (SD 19.0) vs 66.4 (SD 15.8); P=.37; - Proportion of participants gaining/losing BCVA letters from baseline:; - Gaining ≥15 letters: 24% vs 19%; - Maintaining BCVA (<15 letters change): 65% vs 76%; - Losing ≥15 letters: 11% vs 5%; - Number of switchers: 6% vs 5% | G1 vs G2 vs G3 vs G4; - Mean change in BCVA; - 12 months: 8.0 (SD 16) vs 8.5 (SD 14) vs 5.9 (SD 16) vs 6.8 (SD 13); P=.16; ○ Longitudinal regression model, estimated mean change: 7.3 (SE 0.8) vs 7.2 (SE 0.7) vs 6.1 (SE 0.7) vs 6.4 (SE 0.6); P=.53; - 24 months: 7.8 (SD 15.5) vs 8.8 (SD 15.9) vs 5.0 (SD 17.9) vs 6.7 (SD 14.6); P=.21 between drugs; ○ Longitudinal regression model, estimated mean change: 0.7 letters (95% CI, -0.9 to 2.3), P=.41; - Mean BCVA achieved:; - 12 months: 68.4 (SD 18.2) vs 68.8 (SD 17.7) vs 66.5 (SD 19.0) vs 68.4 (SD 16.4); P=.45; - 24 months: 68.2 (SD 16.1) vs 68.5 (SD 18.9) vs 66.0 (SD 19.9) vs 68.5 (15.3); P=. 17 between drugs; - Proportion of participants gaining/losing BCVA letters from baseline:; - 12 months:; ○ Gaining ≥15 letters: 31.3% vs 34.2% vs 28.0% vs 24.9%; P=.09; ○ Gaining 5-14 letters: 37.0% vs 31.7% vs 33.2% vs 36.1%; ○ Maintaining vision (≤4 letters change): 18.9% vs 21.8% vs 26.3% vs 21.8%; ○ Losing 5-14 letters: 6.8% vs 6.7% vs 8.5% vs 8.1%; ○ Losing ≥15 letters: 6.0% vs 5.6% vs 8.5% vs 4.6%; P=.29; - 24 months (patients treated with same dosing regimen for entire 2 years):; ○ Gaining ≥15 letters: 31.8% vs 32.8% vs 28.3% vs 30.7%; ○ Gaining 5-14 letters: 27.9% vs 36.6% vs 31.5% vs 29.5%; ○ Maintaining vision (≤4 letters change): 24.0% vs 16.4% vs 19.5% vs 23.5%; ○ Losing 5-14 letters: 8.5% vs 7.5% vs 9.2% vs 9.1%; ○ Losing ≥15 letters: 7.8% vs 6.7% vs 11.6% vs 7.2%; - Proportion of participants achieving Snellen equivalent of 20/40 or better (>68 ETDRS letters) at 24 months: 60.5% vs 67.9% vs 62.1% vs 63.3%
Anatomic Outcomes (reported in μm unless otherwise indicated) | G1 vs G2; - Mean change in CMT from baseline:; - 12 months: -26.44 vs -27.59; P=.283; - 18 months: -37.96 vs -44.70; P=.281; - Percentage of patients showing improvement in CMT: 60% (mean 78.73 μm) vs 63% (mean 96.5 μm); - Percentage of patients showing deterioration in CMT: 40% (mean 41.4 μm) vs 37% (mean 56.6 μm) | G1 vs G2; - Mean change in CRT: -131 (SD 129) vs -138 (SD 117); P=.31; - Subretinal fluid and intraretinal cysts absent on OCT: 44% vs 59%; P=.020 | G1 vs G2 vs G3 vs G4; - Mean change in total foveal thickness:; - 12 months: -164 (SD 181) vs -196 (SD 176) vs -152 (SD 178) vs -168 (SD 186); P=.03; - 24 months: -180 (SD 196) vs -190 (SD 172) vs -153 (SD 189) vs -166 (SD 190); P=.38 between drugs; - Fluid absent on OCT:; - 12 months: 26.0% vs 43.7% vs 19.2% vs 23.9%; P<.001; - 24 months: 30.2% vs 45.5% vs 13.9% vs 22.3%; P=.0003 between drugs
Harms/Adverse Event (AE) outcomes (in study eye) | G1 vs G2 Minor complications: 11.1% vs 7.3% | G1 vs G2; - ≥1 serious AE: 21.1% vs 22.3%; P=.87; - Number of AEs: 256 vs 299; P=.48; Systemic AEs:; - Death due to serious AE: 0.6% vs 0.6%; P=.6818; - Cardiac disorders: 2.5% vs 3.7%; - Gastrointestinal disorders: 1.2% vs 1.2% | G1 vs G2 vs G3 vs G4 Ocular AEs:; - Endophthalmitis: 1.2% vs 0.7%; P=.38; - Pseudo-endophthalmitis: 0.2% vs 0.2%; P=1.00; Systemic AEs:; - ≥1 serious AEs: 39.9% vs 31.7%; P=.004; adjusted RR 1.30 (95% CI, 1.07 vs 1.57), P=.009; - All-cause death: 6.1% vs 5.3%; P=.62; - Arterial thrombotic events: 5.0% vs 4.7%: P=.89; - Nonfatal stroke: 1.4% vs 1.3%; P=1.00; - Nonfatal MI: 1.2% vs 1.5%; P=.80; - Vascular death: 2.4% vs 2.0%; P=.70; - Venous thrombotic events: 1.7% vs 0.5%; P=.054; - HTN: 0.7% vs 0.5%; P=.72; - Cardiac disorders: 10.6% vs 7.8%; P=.11; - Gastrointestinal disorders: 4.8% vs 1.8%; P=.005; - AEs not previously associated with anti-VEGF treatment (eg, arterial thrombotic events, systemic hemorrhage, congestive heart failure, venous thrombotic events, HTN, and vascular death): 34.5% vs 28.4%; P=.02
Cost and Burden Outcomes | G1 vs G2; - Mean number of injections: 4.3 vs 5.6 | NR | G1 vs G2 vs G3 vs G4; - Mean number of injections :; - 12 months (max 13): 11.9 (SD 1.2) vs 11.7 (SD 1.5) vs 7.7 (SD 3.5) vs 6.9 (SD 3.0); P=.003 between PRN groups; - 24 months (max 26): 23.4 (SD 2.8) vs 22.4 (SD 3.9) vs 14.1 (SD 7.0) vs 12.6 (SD 6.6); P=.01 between PRN groups; - Average cost of drug per patient in US dollars (based on per-dose cost of $50 for bevacizumab and $2,000 for ranibizumab):; - 12 months: 595 vs 23,400 vs 385 vs 13,800; - 24 months: 1,170 vs 44,800 vs 705 vs 25,200
Notes; Subgroup Analyses | - Subgroup analyses:; - Ranibizumab: Mean change in BCVA at 18 months, whole group vs predominantly classic subgroup: 3.55 vs 5.24; - Bevacizumab: Mean change in BCVA at 18 months, whole group vs predominantly classic subgroup: 3.96 vs 5.4 | Non-inferiority trial | - “The data and safety monitoring committee recommended that data for 23 patients at one study center be excluded because of serious protocol noncompliance, so analyses included only the 1185 patients who were enrolled at the remaining 43 centers in the analyses.”; - At 12 months, treatment decisions by study ophthalmologists were consistent with the retreatment protocol for 2336/3268 examinations (71.5%) in the group assigned to ranibizumab PRN and for 2328/3133 examinations (74.3%) in the group assigned to bevacizumab PRN.; - Re-randomization: At 12 months, patients initially assigned to monthly treatment retained their drug assignment but were reassigned randomly to either monthly or as-needed treatment. However, 24-months results recorded here only for patients treated with the same dosing regimen for 2 years.

Study | GEFAL; Kodjikian 2013^34^ | IVAN; Chakravarthy 2013^27,37,38^ | LUCAS; Berg 2015^39,40^
- Follow-up; - Country; - NCT or ID number; - Funding | - 12 months; - France; - NCT01170767; - French Ministry of Health; French Health Insurance System | - 24 months; - UK; - ISRCTN 92166560; - UK National Institute for Health Research Health Technology Assessment programme | - 24 months; - Norway; - NCT01127360; - Oslo University Hospital
Objective | To evaluate the relative efficacy and safety profile of bevacizumab versus ranibizumab intravitreal injections for the treatment of neovascular AMD. | To compare the efficacy and safety of ranibizumab and bevacizumab intravitreal injections to treat neovascular AMD; to estimate the effectiveness of discontinuous versus continuous treatment regimens; and to estimate the cost-effectiveness of the alternative treatment strategies. | To compare the efficacy and safety of bevacizumab versus ranibizumab when administered according to a treat-and-extend protocol for the treatment of neovascular AMD.
Population/Condition | Active subfoveal neovascular AMD. | Active previously untreated neovascular AMD with neovascular lesion involving the center of the fovea. | Previously untreated active neovascular AMD.
Population Characteristics (baseline) | Age: 79.2 years (SD 7.1) Male: 33.7% Mean BCVA: 55.2 (SD 14.0) | Age: 77.7 years Male: 40% Mean BCVA: 61.4 (SD 15.3) More participants in the bevacizumab group than the ranibizumab group had a history of angina (17% vs 11%). | Age: 78.3 years (SD 7.9) Male: 32.5% Mean BCVA: 61 (SD 13.5) Mean CRT: 364.5 μm History of MI (B vs R): 5.6% vs 11.9%; P=.021
Main Inclusion Criteria | Patients aged >50 years with BCVA between 20/32 and 20/320 (Snellen equivalent) measured on the ETDRS chart at a distance of 4 m; active subfoveal neovascular AMD; and total CNV area <12 optic disc areas. | Adults ≥50 years old with previously untreated neovascular AMD in the study eye and BCVA ≥25 letters on the ETDRS chart and a foveal neovascular lesion. Participants without a subfoveal (within 200 μm) neovascular component were eligible if subretinal fluid or serous pigment epithelial detachment was subfoveal. | Age ≥50 years; previously untreated active neovascular AMD in one eye; BCVA between 20/25 and 20/320.
Main Exclusion Criteria | Eyes with subfoveal fibrosis or atrophy; retinal pigment epithelial tear involving the macula; subretinal hemorrhage involving the center of the fovea (>50% of total CNV area); previous treatment with intraocular anti-VEGF or intravenous bevacizumab therapy; history or presence of intraocular inflammation or infection; and uncontrolled systemic HTN despite medical treatment; etc. | Lesions comprising >50% fibrosis or blood (to avoid including inactive or advanced disease); greatest linear diameter >6000 μm; ≥8 diopters of myopia; thick blood involving the center of the fovea; previous treatment (argon laser within 6 months, PDT or a VEGF inhibitor to the study eye); other active ocular disease causing concurrent vision loss. | Pigment epithelial detachments with no associated intraretinal or subretinal edema and lesions comprising more than 50% blood or fibrosis.
Intervention vs Comparator; - Schedule; - Co-Intervention/Rescue Treatment | G1: Bevacizumab 1.25 mg G2: Ranibizumab 0.5 mg; - Schedule (both groups): monthly for 3 months; retreatment afterwards based on OCT or BCVA changes (loss of 5 letters from the previous visit with no obvious atrophy or subretinal fibrosis and fluid on OCT; active exudation on OCT [subretinal fluid unless stable since the last 3 monthly injections, macular edema with intraretinal fluid, or increase in CST of ≥50 μm compared with the previous examination]; increased CNV area or persistence of leakage on angiography since previous visit; or new or persistent subretinal or intraretinal macular hemorrhage). | G1: Ranibizumab 0.5 mg (monthly or PRN) G2: Bevacizumab 1.25 mg (monthly or PRN); - Schedule: All groups received injections monthly for 3 months. Groups in the monthly regimen were treated monthly thereafter. Participants randomized to the PRN groups were not retreated after 3 months unless prespecified clinical and OCT criteria for active disease were met (any subretinal fluid, increasing intraretinal fluid, or fresh blood; uncertainty about these criteria and BCVA had drop of ≥10 letters; or fluorescein leakage >25% of the lesion circumference or expansion of CNV). If retreatment was needed, a further cycle of 3 doses delivered monthly was delivered. | G1: Bevacizumab 1.25 mg G2: Ranibizumab 0.5 mg; - Schedule (both groups): A “treat-and-extend” protocol was employed. Patients were examined and injected every 4 weeks until no signs of active AMD were found. If there were no signs of active neovascular disease, a new injection was given and the period to the next treatment was extended by 2 weeks at a time, up to a maximum interval of 12 weeks. Recurrent disease was defined as any fluid on OCT, new or persistent hemorrhage or dye leakage, or increased lesion size on FA. If examination showed any sign of recurrence, the interval was shortened by 2 weeks at a time, until the disease was considered to be inactive.; - The protocol allowed for withdrawal of patients defined as nonresponders, with the intention of offering patients alternative treatments if available.
N | 501 G1: 191 G2: 183 | 628 (610 analyzed) G1: 323 (314 analyzed) G2: 305 (296 analyzed) | 441 (431 analyzed) G1: 220 (213 analyzed) G2: 221 (218 analyzed) Patients who developed wet AMD in the nonstudy eye received the same drug in both eyes (31 patients in G1 and 25 patients in G2).
Visual Outcomes (ETDRS chart unless otherwise indicated); Functional Status/QOL Outcomes | G1 vs G2; - Mean change in BCVA: 4.82 (SD 14.85) vs 2.93 (SD 15.09); P=.4200; - Mean BCVA achieved: 59.44 (SD 18.52) vs 58.70 (SD 19.82); P=.8632; - Proportion of participants gaining/losing BCVA letters from baseline:; - Gaining ≥15 letters: 20.4% vs 21.3%; P=.8318; - Gaining ≥5 letters: 54.5% vs 49.7%; P=.3607; - Losing ≥5 letters: 20.9% vs 24.6%; P=.4001; - Losing ≥15 letters: 8.9% vs 9.8%; P=.7562 | G1 vs G2; - Mean change in BCVA; - 12 months: 6.4 (SD 12.8) vs 4.7 (SD 12.5); weighted mean difference -1.66 (95% CI, -3.83 to 0.50); - 24 months: 4.9 (SD 15.0) vs 4.1 (SD 13.5); weighted mean difference -0.80 (95% CI, -3.26 to 1.66); - Mean BCVA achieved:; - 12 months: 69.1 (SD 15.7) vs 66.2 (SD 17.1); - 24 months: 67.8 (SD 17.0) vs 66.1 (SD 18.4); mean difference -1.37 (95% CI, -3.75 to 1.01); P=.26; - Proportion of participants gaining/losing BCVA letters from baseline:; - 12 months:; ○ Gaining ≥15 letters: 23% vs 16%; ○ Gaining 5-14 letters: 33% vs 31%; ○ Losing 5-14 letters: 10% vs 14%; ○ Losing ≥15 letters: 5% vs 4%; - 24 months:; ○ Gaining ≥15 letters: 24% vs 16%; ○ Gaining 5-14 letters: 32% vs 34%; ○ Losing 5-14 letters: 12% vs 12%; ○ Losing ≥15 letters: 9% vs 9%; - Bailey-Love Near Word Visual acuity chart, logMAR:; - Mean at 12 months: 0.57 (SD 0.38) vs 0.62 (SD 0.41); GMR 0.92 [95% CI, 0.84 to 1.00]; P=.058; - Mean at 24 months: 0.55 (SD 0.39) vs 0.61 (SD 0.42); GMR 0.94 (95% CI, 0.85 to 1.04), P=.23; - Median change from baseline on Belfast Reading Speed chart:; - Median at baseline: 36.9 (IQR 15.6 to 65.3) vs 35.0 (IQR 14.0 to 69.6); - Median at 12 months: 57.5 (IQR 23.4 to 94.4) vs 51.8 (IQR 11.5 to 94.6); - Median at 24 months: 50.9 (IQR 22.8 to 93.7) vs 52.5 (IQR 9.7 to 90.6); mean difference -1.34 (95% CI, -8.29 to 5.61), P=.70; - Pelli-Robson Contrast Sensitivity chart (letters):; - Mean change from baseline at 12 months: 2.1 (SD 4.9) vs 2.1 (SD 5.0); - Mean change from baseline at 24 months: 1.5 (SD 5.9) vs 1.7 (SD 5.1); mean difference 0.21 (95% CI, -0.62 to 1.04), P=.62.; - Median months from randomization to first treatment failure: 4.9 (IQR 3.2 to 14.0) vs 5.1 (IQR 3.7 to 16.8); HR 1.13 (95% CI, 0.94 to 1.36); P=.18.; - EQ-5D Utility Index (higher score = better utility):; - Median change at 12 months: -0.12 (IQR -0.24 to 0.00) vs -0.13 (IQR -0.26 to 0.00); - Median change at 24 months: -0.15 (IQR -0.27 to 0.00) vs -0.15 (IQR -0.27 to 0.00); score of 1 (“perfect health”) OR 0.89 (95% CI, 0.64 to 1.25), P=.51; - MacDQoL [disease-specific QOL index] (lower score = less impact on QOL):; - Median at 12 months: -1.27 (IQR -2.76 to -0.36) vs -1.18 (IQR -3.14 to -0.39); - Median at 24 months: -1.45 (IQR -2.77 to -0.27) vs -1.39 (IQR -2.73 to -0.41); GMR 1.05 (95% CI, 0.78 to 1.42), P=.74; - MacTSQ treatment satisfaction index (higher score = higher treatment satisfaction):; - Median at 12 months: 66.00 (IQR 61.00 to 69.00) vs 66.00 (IQR 59.50 to 69.00); - Median at 24 months: 66.00 (IQR 61.50 to 70.00) vs 65.00 (IQR 60.00 to 69.00); OR 0.79 (95% CI, 0.54 to 1.16), P=.23 | G1 vs G2; - Mean change in BCVA (ITT analysis):; - 12 months: 7.8 vs 8.0; mean difference 0.2 (95% CI, -2.2 to 2.5), P=.550; - 24 months: 7.8 vs 7.5; mean difference -0.3 (95% CI, -3.2 to 2.7), P=.873; - Mean BCVA achieved:; - 12 months: 67.2 (SD 17) vs 69.6 (SD 15.1); P=.148; - 24 months: 68.0 (SD 17.0) 67.2 (SD 19.1); P=.690; - Proportion of participants gaining/losing BCVA letters from baseline:; - 12 months:; ○ Gaining ≥15 letters: 25.5% vs 26.7%; ○ Gaining ≥5 letters: 36.4% vs 40.6%; ○ Maintaining vision (<4 letters change): 25.5% vs 23.0%; ○ Losing ≥5 letters: 8.7% vs 5.3%; ○ Losing ≥15 letters: 3.8% vs 4.3% -24 months:; ○ Gaining ≥15 letters: 29.9% vs 29.1%; ○ Gaining 5-14 letters: 34.7% vs 34.3%; ○ Maintaining vision (≤4 letters change): 18.0% vs 19.2%; ○ Losing 5-14 letters: 9.6% vs 7.0%; ○ Losing ≥15 letters: 7.8% vs 10.5%
Anatomic Outcomes (reported in μm unless otherwise indicated) | G1 vs G2; - Intraretinal and subretinal fluid absent on OCT: 50.5% vs 58.2%; P=.14; - Change in CST from baseline: -94.96 (SD 132.78) vs -107.23 (SD 103.25); P=.27; - Pigment epithelial detachment on OCT: 33.2% vs 30.6%; 0.596 | G1 vs G2; - Mean change in total thickness at the fovea at 24 months: -146.9 (SD 177.4) vs -133.8 (SD 205.0); GMR 0.96 (95% CI, 0.90 to 1.03), P=.24; - Fluid absent on OCT at 24 months: 50% vs 41%; OR 0.72 (95% CI, 0.50 to 1.02), P=.065 | G1 vs G2; - Mean change in CRT plus subfoveal fluid:; - 12 months: -108 (SD 102) vs -111 (SD 96); mean difference 3 (95% CI, -16 to 22); P=.265.; - 24 months: -111 (SD 116) vs -112 (SD 105); mean difference 1 (95% CI , -22 to 20), P=.923; - Fluid absent on OCT (intraretinal or subretinal):; - 12 months: 47.0% vs 65.2%; P<.001; - 24 months: 55.1% vs 72.1%; P<.001
Harms/Adverse Event (AE) outcomes (in study eye) | G1 vs G2; - ≥1 serious AE: 12.6% vs 12.1%; P=.8757; - Withdrawn due to AE: 2.8% vs 2.9% Ocular AEs:; - Eye disorders: 0.8% vs 2.1%; P=.2791; - Amaurosis fugax: 0% vs 0.4%; - Retinal artery occlusion: 0.4% vs 0%; - Subretinal hematoma: 0.4% vs 0.8%; - Vitreous hemorrhage: 0% vs 0.4%; - Endophthalmitis: 0% vs 0.4%; - Retinal detachment: 0% vs 0%; - Traumatic cataract: 0% vs 0%; Systemic AEs:; - ≥1 systemic serious AE: 12.2% vs 10.0%; P=.4510; - Death: 0.8% vs 1.3%; P=.6818; - Arterial thrombotic events:; - MI: 0.4% vs 0.4%; P=1.0; - Stroke: 0% vs 0%; P=1.0; - Venous thrombotic events:; - Pulmonary embolism: 0.4% vs 0.0%; P=1.0; - Phlebitis: 0% vs 0%; P=1.0; - TIA: 0% vs 0%; P=1.0; - HTN: 0.4% vs 0.8%; P=.6189; - Gastrointestinal disorder: 2.3% vs 2.3%; P=.994 | G1 vs G2; - ≥1 serious AE: 28.3% vs 27.7%; - Withdrawals due to serious AEs: 1.3% vs 1.9%; Ocular AEs:; - ≥1 ocular AE: 2.0% vs 2.5%; - Endophthalmitis: 0% vs 0%; - Retinal detachment: 0% vs 0.3%; - Retinal hemorrhage: 0% vs 0.3%; - Retinal pigment epithelial tear: 0.3% vs 1.0%; - Traumatic cataract: 0.3% vs 0.3%; - Vitreous hemorrhage: 0.3% vs 0%; - RVO: 0% vs 0.3%; - Uveitis: 0.3% vs 0%; - Infection: 0.3% vs 0.0%; Systemic AEs:; - ≥1 serious systemic AE: 27.0% vs 25.8%; OR 0.96 (95% CI, 0.66 to 1.39), P=.82; - All-cause death: 5.1% vs 4.8%; OR 0.96 (95% CI, 0.46 to 2.02), P=.91; - Any vascular event, heart failure, or all-cause death: 9.5% vs 12.1%; OR 1.36 (95% CI, 0.80 to 2.29); P=.25; - Arterial thrombotic event: 3.4% vs 4.1%; OR 1.24 (95% CI, 0.53 to 2.86); - Non-fatal MI: 1.4% vs 1.3%; - Non-fatal stroke: 1.0% vs 1.9%; - Vascular death: 1.4% vs 1.0%; - Heart failure: 0.7% vs 2.2%; - Arterial thrombotic event or heart failure: 4.1% vs 6.4%; OR 1.69 (95% CI, 0.80 to 3.57), P=. 16; - Venous thrombotic events: 1.4% vs 1.0%; - TIA: 0.3% vs 0.3%; - Hospitalized for angina: 1.0% vs 2.2%; - Cardiac disorders: 6.4% vs 6.4%; - Gastrointestinal disorders: 3.0% vs 1.0%; OR 0.31 | G1 vs G2; - Withdrawal due to AE: 7.3% vs 4.1%; Ocular AEs:; - Endophthalmitis: 0.5% vs 0%; P=.499; - Pseudo-endophthalmitis: 1.4% vs 0%; P=.123; - Macular hemorrhage: 1.4% vs 0.0%; P=.123; - Retinal tear: 0.5% vs 0%; P=.499; - Pigment epithelial rupture: 0.5% vs 0%; P=.499; - Acute glaucoma: 0.5% vs 0%; P=.499; Systemic AEs:; - ≥1 serious systemic AE: 29.1% vs 30.3%; P=.778; - All-cause death: 6.8% vs 5.9%; P=.687; - Arterial thrombotic events: 4.1% vs 6.3%; P=.289; - Nonfatal MI: 1.4% vs 4.1%; P=.080; - Nonfatal stroke: 1.4% vs 1.8%; P=1.0; - Vascular death: 1.4% vs 0.9%; P=685; - Venous thrombotic events: 0% vs 1.4%; P=.248; - TIA: 1.4% vs 0%; P=.123; - HTN: 0.9% vs 0.9%; P=1.0; - Cardiac disorder: 5.5% vs 8.6%; P=.197; - Gastrointestinal disorder: 3.2% vs 5.0%; P=.341
Cost and Burden Outcomes | G1 vs G2; - Mean number of injections: 6.8 (SD 2.7) vs 6.5 (SD 2.4); P=.39; - Patients requiring monthly injections: 4.2% vs 1.6%; P=.14 | G1 vs G2; - Median number of treatments: 18 (IQR 11 to 23) vs 19 (IQR 12 to 23) | G1 vs G2; - Mean number of injections:; - 12 months: 8.9 (SD 2.6) vs 8.0 (SD 2.3); P=.001; - 24 months: 18.2 vs 16.0; mean difference 1.2 (95% CI, -3.4 to -1.0), P≤.001; Average treatment interval in weeks: 6.5 vs 7.6; - Proportion of patients receiving injections at treatment interval:; - 4 weeks: 27% vs 20%; P=.002; - 12 weeks: 10% vs 17%; P=.002
Notes; Subgroup Analyses | Non-inferiority trial | 4 exclusions (3 patients wrong drug injected; 1 patient was not treatment naïve).; - Subgroup Analyses: No statistically significant differences were found for the drug or treatment regimen comparisons (P≥.26) for the following subgroup analyses: baseline BCVA in fellow eye, baseline retinal angiomatous proliferation, baseline lesion, baseline CNV size, baseline BCVA, hemorrhage was present at baseline, study eye ≥5 letters better than in the fellow eye at baseline. | - Non-inferiority study; - All 9 patients from 1 study center were excluded because of serious protocol violations, and 1 patient was excluded after a serious retinal and vitreous hemorrhage a few days after inclusion.

Study | MANTA; Krebs 2013^35^ | Scholler 2014^29^ | Subramanian 2010^26^
- Follow-up; - Country; - NCT or ID number; - Funding | - 12 months; - Austria; - NCT00710229; - Austrian Ophthalmologic Society, Ludwig Boltzmann Institute of Retinology and Biomicroscopic Lasersurgery | - 12 months; - Austria; - Unclear (registration numbers provided appear to be for a different trial); - NR | - 12 months; - US; - ISRCTN 73359806; - VA Boston Healthcare System
Objective | To examine whether bevacizumab is inferior to ranibizumab with respect to maintaining/improving visual acuity. | To evaluate the number of needed injections within one year of treatment. | To compare bevacizumab to ranibizumab for treatment of AMD in terms of visual and anatomic outcomes.
Population/Condition | Active primary or recurrent subfoveal lesion with CNV secondary to AMD. | Active previously untreated neovascular AMD | Symptomatic CNV affecting the foveal center secondary to AMD
Population Characteristics (baseline) | Age: 77.2 years (SD 8.0) Male: 36.3% Mean BCVA: 56.7 (SD 13.3) | Age: 80.1 years (SD 6.7) Male: 29.1% Mean BCVA: 58.0 (SD 11.7) Mean CRT: 422 μm (SD 124) | Age: 78.6 years Male: 95% Caucasian: 100% Mean BCVA (B vs R): 34.9 (range 12-60) vs 32.7 (range 4-66); P=.80 Classic or predominantly classic CNV (B vs R): 20% vs 14%
Main Inclusion Criteria | Treatment naive patients >50 years with active primary or recurrent subfoveal lesion with CNV secondary to AMD; BCVA using ETDRS 20/40 to 20/320. If both eyes were eligible for inclusion in the present study, the eye that showed more progression (loss of distance acuity) based on the local investigator's assessment was included. | Age ≥50 years; neovascular AMD verified by fluorescence angiography; BCVA between 20/40 and 20/320. | Age >50 years; presence of a symptomatic CNV (confirmed by intravenous fluorescein angiogram and OCT) affecting the foveal center; baseline BCVA ≥20/400.
Main Exclusion Criteria | Prior treatment with any intravitreal drug or verteporfin PDT in the study eye; prior treatment with systemic bevacizumab or any intravitreal drug; subfoveal fibrosis or atrophy in the study eye >50%; active intraocular inflammation; acute or recurrent infectious conjunctivitis; history of MI and/or stroke. | Previous AMD treatment; previous systemic bevacizumab treatment; vision impairing cataract or other ophthalmologic disease like glaucoma, active inflammation, diabetic retinopathy, etc. | Previous treatment for wet AMD within the past year; presence of subretinal hemorrhage >50% of the size of the lesion on FA; presence of advanced glaucoma; history of malignant or uncontrolled HTN, intraocular inflammation, or history of thromboembolic phenomena.
Intervention vs Comparator; - Schedule; - Co-Intervention/Rescue Treatment | G1: Bevacizumab 1.25 mg G2: Ranibizumab 0.5 mg; - Schedule (both groups): monthly for 3 months; retreatment afterwards based on OCT or BCVA changes (BCVA loss of ≥5 letters with OCT or fluorescein angiographic evidence of fluid in the macula; an increase in CRT ≥100 μm; new macular hemorrhage; new area of classic CNV; or evidence of persistent fluid on OCT ≥1 month after the previous injection). | G1: Bevacizumab 1.25 mg G2: Ranibizumab 0.5 mg; - Schedule (both groups): monthly for 3 months; retreatment afterwards based on OCT or BCVA changes (loss of BCVA of ≥5 letters with OCT evidence of fluid in the macula; increase in CRT of ≥ 100 μm; new area of AMD; new macular hemorrhage; persistent fluid on OCT ≥1 month after the previous injection). | G1: Bevacizumab (dose not reported) G2: Ranibizumab (dose not reported); - Schedule (both groups): monthly for 3 months; retreatment afterwards based on OCT or BCVA changes and clinical examination (qualitative increase in intraretinal or subretinal fluid by OCT; if any significant worsening of visual acuity or increase in fluid or hemorrhage present on clinical examination, a repeat FA was administered with possible re-injection based on the results).; - Patients were treated with topical antibiotics for 4 days after injection.
N | 317 G1: 154 G2: 163 | 55 (number analyzed unclear) G1: 29 G2: 26 | 28 (22 analyzed) G1: 20 (15 analyzed) G2: 8 (7 analyzed)
Visual Outcomes (ETDRS chart unless otherwise indicated); Functional Status/QOL Outcomes | G1 vs G2; - Mean change in BCVA: 4.9 vs 4.1; P=.78; - Mean BCVA achieved: 62.2 (95% CI, 60.1 to 64.3) vs 60.7 (95% CI, 58.7 to 62.8); - Proportion of participants gaining/losing BCVA letters from baseline (all estimated from graph):; - Gaining ≥15 letters: 23% vs 21%; P=.42; - Gaining ≥5 letters: 58% vs 53%; P=.31; - Losing ≥5 letters: 21% vs 21%; P=. 11; - Losing ≥15 letters: 5% vs 6%; P=.23 | G1 vs G2; - Mean BCVA achieved: 64.75 (SD 17.03) vs 59.12 (SD 16.64); mean difference 5.5, P=.631; - Proportion of participants losing ≥15 letters from baseline: 6.9% vs 7.7% | G1 vs G2; - Mean change in BCVA: 7.6 vs 6.3; P=.74; - Mean BCVA achieved: 42.5 (SD 13.7) vs 39.0 (SD 10.1); P=.5; - Proportion of participants gaining/losing BCVA letters from baseline:; - Gaining ≥15 letters: 33% vs 14%; - Gaining ≥5 letters: 60% vs 57%; - Losing ≥5 letters: 27% vs 14%; - Losing ≥15 letters: 0% vs 14%; *NOTE: BCVA measured using ETDRS at 2 m instead of recommended 4 m; vision was recorded in the same, consistent fashion for all study subjects.
Anatomic Outcomes (reported in μm unless otherwise indicated) | G1 vs G2; - Mean change in CRT (corrected values): -86.3 vs -89.9; P=.81 | G1 vs G2; - Mean CRT: 350.47 (SD 102.84) vs 315.67 (SD 65.86); P=.088 | G1 vs G2; - Mean change in CMT: -50 vs -91; P=.29
Harms/Adverse Event (AE) outcomes (in study eye) | G1 vs G2; - Total number of AEs: 19 (12.3%) vs 15 (9.2%); P=.37; Ocular AEs: 0 (0%) vs 0 (0%); P=1.0 Systemic AEs:; - Death: 3 (1.9%) vs 2 (1.2%); P=.61; - Vascular disorders:; - Heart attack: 3 (1.9%) vs 2 (1.2%); P=.61; - Stroke: 1 (0.6%) vs 1 (0.6%); P=.94; - Mesenteric artery occlusion: 1 (0.6%) vs 0 (0%); P=.30; - Non-vascular disorders:; - Infection: 3 (1.9%) vs 3 (1.8%); P=.94; - Injury or procedural complication: 2 (1.3%) vs 3 (1.8%); P=.70; - Surgical or medical procedure: 1 (0.6%)vs 0 (0%); P=.30; - Any system organ class: 3 (1.9%) vs 2 (1.2%); P=.61 | G1 vs G2 Ocular AEs:; - Subretinal bleeding: 0% vs 7.7%; Systemic AEs:; - TIA: 0% vs 3.8% | No major ocular AEs or systemic AEs reported in any subjects who completed the one-year follow-up visit. Minor AEs (eg, subconjunctival hemorrhage, transient post-injection pain, and elevated IOP) data not reported. No reports of anterior chamber inflammation, vitreous hemorrhage, retinal detachment, endophthalmitis, or systemic AEs in patients completing one-year follow-up.
Cost and Burden Outcomes | G1 vs G2; - Mean number of re-treatments: 6.1 (SD 2.8) vs 5.8 (SD 2.7); P=.26 | G1 vs G2; - Mean number of injections: 5.80 (SD 2.28) vs 5.00 (SD 1.67); P=.084 | G1 vs G2; - Mean number of injections: 8 (range 3-8) vs 4 (3-6); P=.001
Notes; Subgroup Analyses | Non-inferiority approach (power calculated assuming 7 letter increase in BCVA with ranibizumab and no change in BCVA with bevacizumab). The study was not powered to determine AEs of statistical significance. | | - VA Boston Healthcare System Hospital.; - Inclusion criteria amended from BCVA 20/40 to 20/200, to BCVA ≥20/400.; - BCVA measured at 2 m instead of recommended 4 m because of exam room size; vision was recorded in the same, consistent fashion for all study subjects.

Study | VIEW 1; Heier 2012^43^ | VIEW 2; Heier 2012^43^ | VIEW 1 and VIEW 2 combined 96-week results; Schmidt-Erfurth 2014^44^
- Follow-up; - Country; - NCT or ID number; - Funding | - 12 months; - US and Canada; - NCT00509795; - Regeneron Pharmaceutical and Bayer HealthCare | - 12 months; - Europe, the Middle East, Asia-Pacific, and Latin America; - NCT00637377; - Regeneron Pharmaceutical and Bayer HealthCare | - 22 months; - US, Canada, Europe, the Middle East, Asia-Pacific, and Latin America; - NCT00509795 and NCT00637377; - Regeneron Pharmaceutical and Bayer HealthCare
Objective | To compare monthly and every-2-month dosing of intravitreal aflibercept injection with monthly ranibizumab in patients with neovascular AMD. | To compare monthly and every-2-month dosing of intravitreal aflibercept injection with monthly ranibizumab in patients with neovascular AMD. | To compare monthly and every-2-month dosing of intravitreal aflibercept injection with monthly ranibizumab in patients with neovascular AMD.
Population/Condition | Active subfoveal CNV lesions or juxtafoveal lesions with leakage affecting the fovea, secondary to AMD. | Active subfoveal CNV lesions or juxtafoveal lesions with leakage affecting the fovea, secondary to AMD. | Active subfoveal CNV lesions or juxtafoveal lesions with leakage affecting the fovea, secondary to AMD.
Population Characteristics (baseline) | Age: 78 years (SD 8.0) Male: 41.2% White: 96.6% Baseline BCVA: 55.1 (SD 13.1) Predominantly classic lesion: 26.5%; Minimally classic lesion: 34.1%; Occult lesion: 38.3% | Age: 73.9 years (SD 8.7) Male: 44.5% White: 72.8% Baseline BCVA: 52.4 (SD 13.9) Predominantly classic lesion: 25.8%; Minimally classic lesion: 35.3%; Occult lesion: 38.4% | Age: 75.9 years (SD 8.6) Male: 42.8% White: 84.7% Baseline BCVA: 53.8 (SD 13.6)
Main Inclusion Criteria | Age ≥50 years; active subfoveal CNV lesions (any subtype) secondary to AMD, or juxtafoveal lesions with leakage affecting the fovea; CNV comprising ≥50% of total lesion size; BCVA between 73 and 25 letters (20/40 to 20/320 Snellen equivalent). | Age ≥50 years; active subfoveal CNV lesions (any subtype) secondary to AMD, or juxtafoveal lesions with leakage affecting the fovea; CNV comprising ≥50% of total lesion size; BCVA between 73 and 25 letters (20/40 to 20/320 Snellen equivalent). | Age ≥50 years; active subfoveal CNV lesions (any subtype) secondary to AMD, or juxtafoveal lesions with leakage affecting the fovea; CNV comprising ≥50% of total lesion size; BCVA between 73 and 25 letters (20/40 to 20/320 Snellen equivalent).
Main Exclusion Criteria | Prior treatment for AMD (including investigational agents or anti-VEGF therapy) in study eye. | Prior treatment for AMD (including investigational agents or anti-VEGF therapy) in study eye. | Prior treatment for AMD (including investigational agents or anti-VEGF therapy) in study eye.
Intervention vs Comparator; - Schedule; - Co-Intervention/Rescue Treatment | G1: Aflibercept 2.0 mg every 4 weeks G2: Aflibercept 0.5 mg every 4 weeks G3: Aflibercept 2.0 mg every 8 weeks (after 3 initial doses every 4 weeks) G4: Ranibizumab 0.5 mg every 4 weeks; - Schedule: Patients were seen every 4 weeks and given either active treatment or a sham injection depending on randomization group (ie, G3 received sham every other visit). | G1: Aflibercept 2.0 mg every 4 weeks G2: Aflibercept 0.5 mg every 4 weeks G3: Aflibercept 2.0 mg every 8 weeks (after 3 initial doses every 4 weeks) G4: Ranibizumab 0.5 mg every 4 weeks; - Schedule: Patients were seen every 4 weeks and given either active treatment or a sham injection depending on randomization group (ie, G3 received sham every other visit). | G1: Aflibercept 2.0 mg every 4 weeks for first 52 weeks, capped PRN thereafter G2: Aflibercept 0.5 mg every 4 weeks for first 52 weeks, capped PRN thereafter G3: Aflibercept 2.0 mg every 8 weeks (after 3 initial doses every 4 weeks) for first 52 weeks, capped PRN thereafter G4: Ranibizumab 0.5 mg every 4 weeks for first 52 weeks, capped PRN thereafter; - Schedule for follow-up phase (weeks 52-96): required a switch of all regimens from fixed monthly or every 2 months regimen to a variable regimen requiring at least quarterly dosing (capped PRN); interim injections allowed based on an assessment of anatomic and visual parameters.
N | 1217 G1: 304 G2: 304 G3: 303 G4: 306 | 1240 G1: 313 G2: 311 G3: 313 G4: 303 | 2457 G1: 617 G2: 615 G3: 616 G4: 609
Visual Outcomes (ETDRS chart unless otherwise indicated); Functional Status/QOL Outcomes | G1 vs G2 vs G3 vs G4; - Mean change in BCVA: 10.9 (SD 13.8) vs 6.9 (SD 13.4) vs 7.9 (SD 15.0) vs 8.1 (SD 15.3); LS mean difference: G1 vs G4: 3.15 (95% CI, 0.92 to 5.37), P=.0054; G2 vs G4: -0.80 (95% CI, -3.03 to 1.43), P=.4793; G3 vs G4: 0.26 (95% CI, -1.97 to 2.49), P=.8179; - Proportion of participants gaining/losing BCVA letters from baseline:; - Maintaining BCVA (losing <15 letters, LOCF): 95.1% vs 95.0% vs 94.4% vs 93.8%; - Gaining ≥0 letters (losing no letters): 83.6% vs 78.1% vs 79.7% vs 78.9%; - Gaining ≥15 letters: 37.5% vs 24.9% vs 30.6% vs 30.9%; LS mean difference: G1 vs G4: 6.58 (95% CI, -0.98 to 14.14), P=.1042; G2 vs G4: -6.00 (95% CI, -13.17 to 1.16), P=.1037; G3 vs G4: -0.36 (95% CI, -7.74 to 7.03), P=.93; - Proportion achieving BCVA 20/40 or better: 45.7% vs 34.9% vs 37.9% vs 34.5%; - Mean change in total NEI VFQ-25 score: 6.7 (SD 13.5) vs 4.5 (SD 11.9) vs 5.1 (SD 14.7) vs 4.9 (SD 14.0); LS mean difference: G1 vs G4: 1.28 (95% CI, -0.73 to 3.28), P=.2090; G2 vs G4: -0.67 (95% CI, -2.69 to 1.35), P=.5128; G3 vs G4: -0.60 (95% CI, -2.61 to 1.42), P=.5579 | G1 vs G2 vs G3 vs G4; - Mean change in BCVA: 7.6 (SD 12.6) vs 9.7 (SD 14.1) vs 8.9 (SD 14.4) vs 9.4 (SD 13.5); LS mean difference: G1 vs G4: -1.95 (95% CI, -4.10 to 0.20), P=.076; G2 vs G4: -0.06 (95% CI, -2.24 to 2.12), P=.955; G3 vs G4: -0.90 (95% CI, -3.06 to 1.26), P=.4131; - Proportion of participants gaining/losing BCVA letters from baseline:; - Maintaining BCVA (losing <15 letters): 94.5% vs 95.3% vs 95.4% vs 94.8%; - Gaining ≥0 letters (losing no letters): 78% vs 83.1% vs 81.7% vs 79%; - Gaining ≥15 letters: 29.4% vs 34.8% vs 31.4% vs 34.0%; LS mean difference: G1 vs G4: -4.57 (95% CI, -12.02 to 2.88), P=.229; G2 vs G4: 0.78 (95% CI, -6.91 to 8.46), P=.843; G3 vs G4: -2.65 (95% CI, -10.18 to 4.88), P=.490; - Proportion achieving BCVA 20/40 or better: 32.7% vs 32.4% vs 27.5% vs 35.7%; - Mean change in total NEI VFQ-25 score: 4.5 (SD 15.0) vs 5.1 (SD 13.7) vs 4.9 (SD 14.7) vs 6.3 (SD 14.8); LS mean difference: G1 vs G4: -2.79 (95% CI, -4.90 to -0.68), P=.0097; G2 vs G4: -0.93 (95% CI, -3.07 to 1.20), P=.3917; G3 vs G4: -1.95 (95% CI, -4.07 to 0.17), P=.0717 | G1 vs G2 vs G3 vs G4; - Mean change in BCVA at 22 months: 7.6 vs 6.6 vs 7.6 vs 7.9; - Proportion of participants gaining/losing BCVA letters from baseline:; - Maintaining vision (losing <15 letters): 92.2% vs 91.5% vs 92.4% vs 91.6%; - Gaining ≥15 letters : 31.2% vs 28.1% vs 33.4% vs 31.6%
Anatomic Outcomes (reported in μm unless otherwise indicated) | G1 vs G2 vs G3 vs G4; - Mean change in CNV area (mm^2^): -4.6 (SD 5.5) vs -3.5 (SD 5.3) vs -3.4 (SD 6.0) vs -4.2 (SD 5.6); LS mean difference: G1 vs G4: -0.33 (95% CI, -1.04 to 0.38), P=.3575; G2 vs G4: 0.71 (95% CI, -0.01 to 1.42), P=.0507; G3 vs G4: 0.86 (95% CI, 0.15 to 1.58), P=.0173.; - Mean change in CRT: -116.5 (SD 98.4) vs -115.6 (SD 104) vs -128.5 (SD 108.5) vs -116.8 (SD 109); - Proportion with dry retina (no cystic intraretinal edema or subretinal fluid on OCT): 64.8% vs 56.7% vs 63.4% vs 63.6% | G1 vs G2 vs G3 vs G4; - Mean change in CNV area (mm^2^): -6.0 (SD 6.1) vs -4.2 (SD 6.1) vs -5.2 (SD 5.9) vs -4.2 (SD 5.9); LS mean difference: G1 vs G4: -1.18 (95% CI, -1.98 to -0.38); G2 vs G4: -0.17 (95% CI, -0.63 to 0.97); G3 vs G4: -0.73 (95% CI, -1.53 to 0.07); - Mean change in CRT: -156.8 (SD 122.8) vs -129.8 (SD 114.8) vs -149.2 (SD 119.7) vs -138.5 (SD 122.2); - Proportion with dry retina (no cystic intraretinal edema or subretinal fluid on OCT): 80.3% vs 63.9% vs 71.9% vs 60.4% | G1 vs G2 vs G3 vs G4; - Mean change in CRT at 22 months: -128 vs -113 vs -133 vs -128; - Proportion with retinal fluid absent on OCT: 54.4% vs 44.6% vs 50.1% vs 45.5%
Harms/Adverse Event (AE) outcomes (in study eye) | G1-3 (all aflibercept groups) vs G4; - Withdrawal due to AE: 12 (1.3%) vs 4 (1.3%); Ocular AEs:; - Patients with ≥1 serious ocular AE: 16 (1.8%) vs 10 (3.3%); - Endophthalmitis: 3 (0.3%) vs 3 (1.0%); - Retinal hemorrhage: 2 (0.2%) vs 2 (0.7%); - Increased IOP: 41 (4.5%) vs 22 (7.2%); - Treatment-emergent serious retinal detachment: 1 (0.1%) vs 0 (0%); - Treatment-emergent serious cataract: 1 (0.1%) vs 0 (0%); Systemic AEs:; - Serious systemic or nonocular AEs: 141 (15.5%) vs 57 (18.8%); - Any arterial thrombotic event: 15 (1.6%) vs 5 (1.6%); - Vascular death: 5 (0.5%) vs 1 (0.3%); - Nonfatal MI: 6 (0.7%) vs 4 (1.3%); - Nonfatal stroke: 4 (0.4%) vs 0%; - HTN: 82 (9.0%) vs 29 (9.5%); - Venous thromboembolic event: 1 (0.1%) vs 1 (0.3%); - Congestive heart failure: 4 (0.4%) vs 2 (0.7%); - Gastrointestinal perforation or fistula: 0 (0%) vs 0 (0%); - Nonocular hemorrhagic event: 7 (0.7%) vs 1 (0.3%) | G1-3 (all aflibercept groups) vs G4; - Withdrawal due to AE: 23 (2.5%) vs 2 (0.7%); Ocular AEs:; - Patients with ≥1 serious ocular AE: 20 (2.2%) vs 9 (3.1%); - Endophthalmitis: 0% vs 0%; - Retinal hemorrhage: 4 (0.4%) vs 1 (0.3%); - Increased IOP: 54 (5.9%) vs 19 (6.5%); - Treatment-emergent serious retinal detachment: 2 (0.2%) vs 1 (0.3%); - Treatment-emergent serious cataract: 2 (0.2%) vs 1 (0.3%); Systemic AEs:; - Serious systemic or nonocular AEs: 111 (12.2%) vs 26 (8.9%); - Any arterial thrombotic event: 17 (1.9%) vs 5 (1.7%); - Vascular death: 4 (0.4%) vs 1 (0.3%); - Nonfatal MI: 9 (1.0%) vs 2 (0.7%); - Nonfatal stroke: 4 (0.4%) vs 2 (0.7%); - HTN: 81 (8.8%) vs 29 (10.0%); - Venous thrombotic events: 0 (0%) vs 0 (0%); - Congestive heart failure: 1 (0.1%) vs 1 (0.3%); - Gastrointestinal perforation or fistula: 2 (0.2%) vs 0 (0%); - Nonocular hemorrhagic event: 3 (0.3%) vs 0 (0%) | G1-3 (all aflibercept groups) vs G4; - Withdrawal due to AE by 22 months: 75 (4.1%) vs 16 (2.6%); Ocular AEs:; - ≥1 serious ocular AE: 65 (3.6%) vs 26 (4.4%); - Endophthalmitis: 5 (0.3%) vs 5 (0.8%); - Retinal detachment: 3 (0.2%) vs 3 (0.5%); - Retinal hemorrhage: 13 (0.7%) vs 4 (0.7%); - Retinal pigment epithelial tear: 4 (0.2%) vs 1 (0.2%); - Cataract: 11 (0.6%) vs 1 (0.2%); - Increased IOP: 3 (1.6%) vs 1 (0.2%); - Any intraocular inflammatory response: 15 (0.8%) vs 9 (1.5%); - Posterior capsule opacification: 0 (0%) vs 2 (0.3%); Systemic AEs:; - ≥1 serious systemic or nonocular AE: 437 (24.0%) vs 146 (24.5%); - Arterial thrombotic event: 60 (3.3%) vs 19 (3.2%); ○ Nonfatal MI: 25 (1.4%) vs 12 (2.0%); ○ Nonfatal stroke: 13 (0.7%) vs 5 (0.8%); ○ Vascular death: 24 (1.3%) vs 3 (0.5%); - Congestive cardiac failure: 16 (0.9%) vs 5 (0.8%); - Coronary artery disease: 8 (0.4%) vs 5 (0.8%); - Atrial fibrillation: 23 (1.3%) vs 5 (0.8%); - TIA: 17 (0.9%) vs 1 (0.2%); - Cerebrovascular accident: 14 (0.8%) vs 4 (0.7%); - Death: 52 (2.8%) vs 16 (2.7%)
Cost and Burden Outcomes | NR | NR | G1 vs G2 vs G3 vs G4; - Mean number of injections at week 96: 16.0 (SD 3.2) vs 16.2 (SD 4.0) vs 11.2 (SD 2.9) vs 16.5 (SD 2.7); - Mean number of injections from week 52-96 (PRN schedule): 4.1 (SD 1.8) vs 4.6 (SD 2.2) vs 4.2 (SD 1.7) vs 4.7 (SD 2.2); P<.0001 G1 vs G4; P<.0001 G3 vs G4
Notes; Subgroup Analyses | Non-inferiority study. Not powered to detect differences in rare but serious intraocular complications (eg, endophthalmitis). | Non-inferiority study. Not powered to detect differences in rare but serious intraocular complications (eg, endophthalmitis).

## Trials in Patients with Diabetic Macular Edema (DME)

Study | DRCR.net (Protocol T); Wells 2016^46-48^ | Ekinci 2014^30^ | Nepomuceno 2013^31^
- Follow-up; - Country; - NCT or ID number; - Funding | - 24 months; - US; - NCT01627249; - National Institutes of Health. Regeneron Pharmaceuticals provided the aflibercept at no cost, and Genentech provided the ranibizumab at no cost for the study. | - 12 months; - Turkey; - NR; - NR (“The authors have no relevant affiliations or financial involvement with any organization or entity with a financial interest in or financial conflict with the subject matter”) | - 11 months (48 weeks); - Brazil; - NCT01487629; - São Paulo Research Foundation, Fundação de Apoio ao Ensino, Pesquisa e Assistência do Hospital das Clínicas da Faculdade de Medicina de Ribeirão Preto da Universidade de São Paulo
Objective | To compare intravitreal aflibercept, bevacizumab, and ranibizumab for the treatment of DME involving the center of the macula and causing vision impairment. | To compare the effects of bevacizumab and ranibizumab on visual acuity and foveal thickness in macular edema due to diabetic retinopathy. | To compare visual acuity and spectral-domain OCT outcomes associated with intravitreal bevacizumab versus ranibizumab for the management of DME.
Population/Condition | DME involving the macular center | Clinically significant DME | DME with central involvement
Population Characteristics (baseline) | Age: 60.6 years (SD 10) Male: 54% White: 65% Black/African American: 16% Hispanic: 16% Mean BCVA: 64.8 (SD 11.3) Type 2 diabetes: 90.6% (mean duration 17 years) Mean HbA1c: 7.7 Mean CST: 412 μm (SD 130) | Age: 66.5 years (SD 11.5) Male: 36% Mean BCVA, B vs R (Snellen chart): 0.22 (SD 0.11) vs 0.24 (SD 0.12) Mean foveal thickness, B vs R: 483.8 (SD 126) vs 489.8 (SD 141) Mean duration of diabetes: 15.5 years (SD 3.3) Mean HbA1c level: 7.3 (SD 0.6) | Age: 63.8 years (SE 8.9) Male: 45% White: 70% Mean BCVA (logMAR, B vs R): 0.63 (SE 0.06) vs 0.60 (SE 0.05); P=.680 Baseline CST (B vs R): 451 μm (SE 22) vs 421 μm (SE 23); P=.406 Mean duration of DME: 3.1 years Mean duration of diabetes: 16 years Mean HbA1c: 8.6 (SD 1.6) Moderate or severe nonproliferative diabetic retinopathy: 60% Diabetic retinopathy treated with PRP ≥6 months before enrollment: 40%
Main Inclusion Criteria | ≥18 years of age; type 1 or 2 diabetes; at least one eye with a BCVA letter score of 78 to 24 and center-involved DME on clinical examination and OCT according to protocol-defined thresholds; and received no anti-VEGF treatment within the previous 12 months. | Clinically significant DME (CMT >300 μm), as found through FA and OCT evaluations and dilate fundus examination, after 1-year follow-up period. | Center-involved DME, defined as a CST >300 μm on OCT, despite ≥1 session of macular laser photocoagulation performed at least 3 months previously; BCVA between 0.3 logMAR (Snellen equivalent: 20/40) and 1.6 logMAR (Snellen equivalent: 20/800).
Main Exclusion Criteria | Substantial cataract; significant renal disease; unstable medical status including blood pressure, cardiovascular disease, and glycemic control; MI, other acute cardiac event requiring hospitalization, stroke, TIA, or treatment for acute congestive heart failure within 4 months of randomization. | Patients who received intravitreal treatment at another center; PRP, grid or focal laser photocoagulation application within 6 months; intraocular surgery within 6 months; acute ocular infection, stroke, MI, uncontrolled HTN, pregnancy, renal failure and cataract formation during the follow-up period. | Vitreomacular traction on OCT; history of glaucoma or ocular HTN; systemic corticosteroid therapy; any condition that might preclude follow-up throughout the study period; last anti-VEGF or steroid treatment >6 months before enrollment.
Intervention vs Comparator; - Schedule; - Co-Intervention/Rescue Treatment | G1: Aflibercept 2.0 mg G2: Bevacizumab 1.25 mg G3: Ranibizumab 0.3 mg; - Schedule (all groups): Administered every 4 weeks unless visual acuity was 20/20 or better with a CST below the eligibility threshold and there was no improvement (≥5 letters or ≥10% decrease in thickness) or worsening in response to the past two injections.; - The use of pre-injection or post-injection antibiotics was at the investigator's discretion. Laser photocoagulation therapy (focal, grid, or both) was initiated at or after the 24-week visit for persistent DME. Treatment for DME other than the randomly assigned anti-VEGF agent or laser therapy was permitted if a study eye met the criteria for treatment failure. | G1: Bevacizumab 1.25 mg G2: Ranibizumab 0.05 mg* (*possible reporting error, as typical dose is 0.3 mg); - Schedule (both groups): Administered monthly for 3 months. An additional 3 monthly injections were applied if the CMT was >275 μm or if there was an increase in BCVA of ≥3 letters compared with baseline. After the 6th intravitreal injection, if the CMT >275 μm or if there was an increase in BCVA of ≥2 letters, additional intravitreal injections were performed until stable visual acuity was obtained.; - Topical antibiotics 4 times daily for 1 week. | G1: Bevacizumab 1.5 mg G2: Ranibizumab 0.5 mg; - Schedule (both groups): Administered monthly if CST was >275 μm.; - Randomization of both eyes: If both eyes were eligible for treatment and the patient agreed to treat both eyes with anti-VEGF therapy, 1 eye received the randomized treatment and the contralateral eye received the other anti-VEGF agent on the next day.; - Focal/grid laser photocoagulation could be used as rescue therapy (at the discretion of ophthalmologist) after 3 injections if there was not a reduction in CST of ≥10% or an increase in BCVA of ≥5 letters compared with baseline; or patient could receive injections for an additional 3 consecutive visits.; - Patients were instructed to instill 1 drop of 0.3% ciprofloxacin into the injected eye 4 times daily for 1 week after the procedure.
N | 660 G1: 224 G2: 218 G3: 218 | 100 G1: 50 G2: 50 | 48 (63 eyes); 45 (60 eyes) analyzed G1: (32 eyes) G2: (28 eyes) *15 patients with bilateral DME received bevacizumab in one eye and ranibizumab in the other eye.
Visual Outcomes (ETDRS chart unless otherwise indicated); Functional Status/QOL Outcomes | G1 vs G2 vs G3; - Mean change in BCVA; - 12 months: 13.3 (SD 11.1) vs 9.7 (SD 10.1) vs 11.2 (SD 9.4); P<.001 for G1 vs G2, P=.03 G1 vs G3, P=.12 G2 vs G3; - 24 months: 12.8 (SD 12.4) vs 10.0 (SD 11.8) vs 12.3 (SD 10.5); P=.02 for G1 vs G2, P=.47 G1 vs G3, P=.11 G2 vs G3; - Proportion of participants gaining/losing BCVA letters from baseline:; - 12 months:; ○ Gaining ≥15 letters: 42% vs 29% vs 32%; P=.028 for G1 vs G2, P=.068 G1 vs G3, P=.51 G2 vs G3; ○ Gaining ≥10 letters: 63% vs 52% vs 59%; P=.021 for G1 vs G2, P=.25 G1 vs G3, P=. 15 G2 vs G3; ○ Losing ≥10 letters: 2% vs 3% vs 1%; P=.83 for all comparisons; ○ Losing ≥15 letters: 1% vs 1% vs 1%; P=.98 for all comparisons; - 24 months:; ○ Gaining ≥15 letters: 39% vs 35% vs 37%; P=.70 for all comparisons; ○ Gaining ≥10 letters: 62% vs 54% vs 59%; P=.22 for G1 vs G2, P=.51 G1 vs G3, P=.50 G2 vs G3; ○ Losing ≥10 letters: 4% vs 6% vs 2%; P=.49 for G1 vs G2, P=.39 G1 vs G3, P=. 15 G2 vs G3; ○ Losing ≥15 letters: 2% vs 3% vs 2%; P=.84 for all comparisons; - Mean BCVA achieved: 77.8 (SD 11.5) vs 74.6 (SD 14.5) vs 77.1 (SD 12.4); - Mean change in BCVA according to baseline visual acuity, see Notes; Subgroup Analyses row below | G1 vs G2; - BCVA achieved (Snellen chart): 0.38 (SD 0.12) vs 0.39 (SD 0.11); P=NS | G1 vs G2; - Mean BCVA improvement at 48 weeks (logMAR): 0.23 (SD 0.02) vs 0.29 (SD 0.04); - Mean BCVA achieved (logMAR): 0.36 (SE 0.05) vs 0.34 (SE 0.04); P=.1886; - Proportion of participants gaining BCVA letters from baseline:; - Gaining ≥15 letters: 39% vs 48%; P=NS; - Gaining ≥ 10 letters: 61% vs 68%; P=NS
Anatomic Outcomes (reported in μm unless otherwise indicated) | G1 vs G2 vs G3; - Mean change in CST:; - 12 months: -169 (SD 138) vs -101 (SD 121) vs -147 (SD 134); P<.001 for G1 vs G2, P=.036 G1 vs G3, P<.001 G1 vs G2; - 24 months: -171 (SD 141) vs -126 (SD 143) vs -149 (SD 141); P<.001 for G1 vs G2, P=.08 G1 vs G3, P<.001 G2 vs G3 | G1 vs G2; - Mean foveal thickness: 342.3 (SD 121) vs 339.3 (SD 121); P=NS | G1 vs G2; - Mean CST at 48 weeks: 329.7 (SE 19.3) vs 280.9 (SE 12.6); P=.4865; - Maximum mean CST reduction: -126 (SE 25) at week 48 vs -136 (SE 23) at week 44; P=NS
Harms/Adverse Event (AE) outcomes (in study eye) | G1 vs G2 vs G3 Ocular AEs:; - Endophthalmitis: 0 (0%) vs 1 (0.5%) vs 0 (0%); P=.66; - Inflammation: 6 (2.7%) vs 3 (1.4%) vs 4 (1.8%); P=.69; - Retinal detachment: 2 (0.9%) vs 2 (0.9%) vs 1 (0.9%); P=1.0; - Retinal tear: 1 (0.4%) vs 1 (0.5%) vs 1 (0.5%); P=1.0; - Vitreous hemorrhage: 15 (6.7%) vs 17 (7.8%) vs 10 (4.6%); P=.37; - Injection-related cataract: 3 (1.3%) vs 2 (0.9%) vs 0 (0%); P=.38; - IOP elevation: 39 (17.4%) vs 27 (12.4+V12%) vs 35 (16.5%); P=.31; Systemic AEs:; - Serious AE: 88 (39.3%) vs 81 (37.2%) vs 82 (37.6%); P=.90; - Vascular events: 12 (5.4%) vs 17 (7.8%) vs 26 (11.9%); P=.047; - Nonfatal MI: 7 (3.1%) vs 3 (1.4%) vs 6 (2.8%); - Nonfatal stroke: 2 (0.9%) vs 6 (2.8%) vs 11 (5.0%); - Vascular death (from any potential vascular or unknown cause): 3 (1.3%) vs 8 (3.7%) vs 9 (4.1%); - All-cause death: 5 (2%) vs 13 (6%) vs 11 (5%); P=.12; - Hospitalization: 77 (34.4%) vs 71 (32.6%) vs 73 (33.5%); P=.93; - Gastrointestinal: 67 (29.9%) vs 64 (29.4%) vs 60 (27.5%); P=.85; - Renal and urinary disorder events: 50 (22.3%) vs 46 (21.1%) vs 35 (16.1%); P=.22; - HTN: 39 (17.4%) vs 27 (12.4%) vs 44 (20.2%); P=.08 | - “Patients with acute ocular infection (endophthalmitis after intravitreal injection, n=3), stroke, MI (n=2), uncontrolled HTN (n=4), renal failure (n=1) and cataract formation during follow-up period (n=4) were excluded from the study.” (not reported by group); - “No complications, like IOP rise or arterial HTN was observed in patients in the study as a result of intravitreal bevacizumab and ranibizumab injections.” | G1 vs G2 (percentages based on number of eyes); - Clinically significant cataract progression: 1 (3%) vs 0 (0%); - Transient vitreous hemorrhage after an acute posterior vitreous detachment: 1 (3%) vs 0 (0%); - Endophthalmitis: 0 (0%) vs 2 (7%); - Increased blood pressure: 0 (0%) vs 1 (4%); - Transient worsening of renal function: 1 patients receiving both treatments
Cost and Burden Outcomes | G1 vs G2 vs G3; - Median number of injections:; - 12 months: 9 (IQR 8 to 11) vs 10 (IQR 8 to 12) vs 10 (IQR 8 to 11); P=.045 for overall comparison; - 24 months: 15 (IQR 11-17) vs 16 (IQR 12-20) vs 15 (IQR 11-19); P=.08 for overall comparison; - Laser photocoagulation performed at least once:; - 12 months: 37% vs 56% vs 46%; P<.001 for overall comparison; - 24 months: 41% vs 64% vs 52%; P<.001 for G1 vs G2, P=.04 G1 vs G3, and P=.01 G2 vs G3 | G1 vs G2; - Mean number of injections: 5.1 (SD 0.74) vs 6.5 (SD 0.85); P<.05 | G1 vs G2; - Mean number of injections: 9.84 (SEM 0.55) vs 7.67 (SEM of the mean 0.60); P=.005; - Rescue therapy:; - Eyes meeting rescue therapy criteria: 9 vs 4; P=.042; - Patients receiving rescue laser therapy: 1 (1 eye) vs 1 (1 eye); - Patients receiving rescue anti-VEGF therapy: 8 (8 eyes) vs 3 (3 eyes)
Notes; Subgroup Analyses | When the other (nonstudy) eye required anti-VEGF treatment (129 participants in the aflibercept group [58%], 122 participants in the bevacizumab group [56%], and 121 participants in the ranibizumab group [56%]), the agent that was used was the same as that used for the study eye.; - Subgroup Analyses: G1 vs G2 vs G3; Subgroup analyses based on baseline visual acuity (<69 vs 69-78 letters); - Patients with letter score <69 at baseline:; ○ Mean change in BCVA at 12 months (n=102 vs n=102 vs n=101): 18.9 (SD 11.5) vs 11.8 (SD 12.0) vs 14.2 (SD 10.6); P<0.001 for G1 vs G2, P=.003 G1 vs G3, P=.21 G2 vs G3; ○ Mean change in BCVA at 24 months (n=98 vs n=92 vs n=94): 18.1 (SD 13.8) vs 13.3 (SD 13.4) vs 16.1 (SD 12.1); P=.02 for G1 vs G2, P=.18 G1 vs G3, P=.18 G2 vs G3; - Patients with letter score 78-69 at baseline:; ○ Mean change in BCVA at 12 months (n=106 vs n=104 vs n=105): 8.0 (SD 7.6) vs 7.5 (SD 7.4) vs 8.3 (SD 6.8); P=.69 for all comparisons; ○ Mean change in BCVA at 24 months (n=103 vs n=93 vs n=97): 7.8 (SD 8.4) vs 6.8 (SD 8.8) vs 8.6 (SD 7.0); P=.51 for G1 vs G2, P=.51 G1 vs G3, P=.31 G2 vs G3; The relative treatment effect on CST also varied according to initial visual acuity (P<0.001). | Excluded patients with certain AEs during follow-up (acute ocular infection, stroke, MI, uncontrolled HTN, pregnancy, renal failure and cataract formation) | If both eyes were eligible for treatment and the patient agreed to treat both eyes with anti-VEGF therapy, 1 eye received the randomized treatment and the contralateral eye received the other anti-VEGF agent on the next day; thus, if an eye was randomized to the ranibizumab group, the contralateral eye was allocated to the bevacizumab group.; - Subgroup Analyses: A multivariate analysis comparing BCVA and CST outcomes between the bevacizumab and ranibizumab groups, taking into account number of injections, baseline BCVA, and CST, demonstrated a statistically significant influence of baseline BCVA on follow-up BCVA (P<.001) but no other significant differences between groups (P=.051) across follow-up time (P=.490) regarding these 2 outcomes.

## Trials in Patients with Macular Edema due to Central Retinal Vein Occlusion (CRVO) or Branch Retinal Vein Occlusion (BRVO)

Study | CRAVE; Rajagopal 2015^32^ | MARVEL; Narayanan 2015^36^
- Follow-up; - Country; - NCT or ID number; - Funding | - 6 months; - US; - NCT01428388; - Barnes Retina Institute | - 6 months; - India; - CTRI/2012/01/003120 (Clinical Trials Registry-India); - Brian Holden Eye Research Center, L.V. Prasad Eye Institute, Hyderabad, India
Objective | To compare efficacy of monthly treatment with bevacizumab or ranibizumab for macular edema due to RVO. | To assess the efficacy and safety of intravitreal bevacizumab compared with ranibizumab in the treatment of macular edema due to BRVO.
Population/Condition | Macular edema secondary to RVO (60% of patients with branch RVO or hemi-RVO, 40% with central RVO) | Center-involving macular edema due to BRVO
Population Characteristics (baseline) | Age: 71.5 years (SD 8.6) Male: 44.9% Mean BCVA (logMAR): 0.745 (SD 0.42) | Age: 51.7 years (SD 8.6) Male: 54.6% (B vs R: 68.4% vs 40.5%) Mean BCVA: 54.4 (SD 12.2) Mean CRT: 469 μm (SD 138)
Main Inclusion Criteria | Age ≥50 years; diagnosis of RVO in the past 9 months, BCVA of 20/40 to 20/320 (Snellen) in study eye (regardless of relative afferent pupillary defect); and CFT >250 μm on OCT. | Age ≥18 years; center-involving macular edema due to BRVO of <9 months duration; minimum CRT of 250 μm in the central subfield on spectral domain OCT); BCVA of 20/40 to 20/320 (73 to 24 letters) in the study eye.
Main Exclusion Criteria | History of intraocular surgery in the study eye including pars plana vitrectomy (but not including uncomplicated cataract surgery) within 60 days; any intravitreal injections within 12 weeks; prior RVO; history of PRP within 3 months of study onset or anticipated within 4 months after study onset; history of cerebrovascular event or MI within 3 months. | Prior episode or bilateral manifestation of RVO; previous panretinal laser photocoagulation or macular laser photocoagulation in the study eye; decrease in BCVA due to causes other than BRVO; history or presence of AMD (dry or wet form); use of intraocular or periocular corticosteroids in the study eye within the previous 3 months; previous treatment with anti-VEGF drugs in the study eye.
Intervention vs Comparator; - Schedule; - Co-Intervention/Rescue Treatment | G1: Bevacizumab 1.25 mg G2: Ranibizumab 0.5 mg; - Schedule (both groups): Patients received monthly injections for 6 months; - Patients were eligible for rescue therapy with focal/grid laser or steroid at any point in the study, at the physician's discretion. Enrolled patients could receive PRP when needed at the discretion of the treating physician | G1: Bevacizumab 1.25 mg G2: Ranibizumab 0.5 mg; - Schedule (both groups): Injection at baseline followed by PRN (met one of following retreatment criteria: >50 μm increase in CRT compared with the thinnest previous measurement; new or persistent cystoid retinal changes or sub-retinal fluid on OCT; loss of ≥5 letters from the best previous BCVA measurement in conjunction with any increase in CRT; increase in BCVA of ≥5 letters between the current and months recent visits).; - Subjects were eligible to receive modified macular grid laser photocoagulation at 12 weeks if the following prespecified criteria were met: >50 μm increase in CRT compared with the thinnest previous measurement, and persistent diffuse edema ≥250 μm in CRT. Whenever laser photocoagulation was performed, an anti-VEGF injection was also administered
N | 98* G1: 49* G2: 49 *Includes 9 patients who were not randomized but were assigned to bevacizumab for financial reasons. | 75 G1: 38 G2: 37
Visual Outcomes (ETDRS chart unless otherwise indicated); Functional Status/QOL Outcomes | G1 vs G2; - Mean change in BCVA (logMAR, using Snellen chart): 0.33 (SD 0.45) vs 0.34 (SD 0.33); P=.38; - Proportion of participants gaining ≥0.3 logMAR units from baseline: 71.4% vs 70.6%; P=.94 | G1 vs G2; - Mean change in BCVA: 15.55 vs 18.08; mean difference: -2.5 letters (95% CI, -8.0 to 5.0), P=.74; - Mean BCVA achieved: 71.7 (SD 10.0) vs 70.9 (SD 13.4); - Proportion of participants gaining ≥15 letters from baseline: 57.8% vs 59.4%; P=1.0; - Proportion of participants achieving BCVA >20/40 (Snellen equivalent): 68.4% vs 62.2%
Anatomic Outcomes (reported in μm unless otherwise indicated) | G1 vs G2; - Mean change in CFT: -212.6 (SD 234.8) vs -243.8 (SD 204.2); P=.72; - Proportion of participants achieving CFT <275 μm (estimated from graph): 65% vs 67%; P=1.0; - Fluid absent on OCT: 56.3% vs 51.4%; P=.81 | G1 vs G2; - Mean change in CRT: -212.7 (SD 234.8) vs -177.1 (SD 204.2); P=.34
Harms/Adverse Event (AE) outcomes (in study eye) | “No instances of ophthalmic serious AEs including endophthalmitis, noninfectious uveitis, retinal detachment, retinal tear, or traumatic cataract were encountered. Injection site pain and irritation were the most AEs. One patient died from complications of pneumonia. No patients suffered MI or cerebrovascular accident during the study.” | G1 vs G2 Ocular AEs:; - Epiretinal membrane: 7.9% vs 0%; - Progression of cataract: 7.9% vs 5.4%; - Elevated IOP: 2.6% vs 0%; - Developed a BRVO in the fellow eye: 0% vs 2.7%; - Endophthalmitis: 0% vs 0%; Systemic AEs:; - Systemic arterial HTN: 5.3% vs 8.1%; - Hospitalization (for fractured foot and fever): 0% vs 5.4%
Cost and Burden Outcomes | NR | G1 vs G2; - Mean number of injections: 3.0 (SD 1.4) vs 3.2 (SD 1.5); - Received rescue grid laser photocoagulation: 21.0% vs 10.8%; P=.34; - Received sector laser photocoagulation due to the development of neovascularization in retina: 2.6% vs 5.4%
Notes; Subgroup Analyses | - “Assistance programs were used to defray any financial hardship, but if it could not be eliminated, then the patient was assigned to the bevacizumab arm (9 patients).”; - “No patient departed from the protocol to receive rescue therapy, and none required PRP.” It is unclear if this means that no patients received rescue therapy with focal/grid laser or steroid according to the protocol.; - Subgroup Analyses: No differences between treatment groups were observed among BRVO or CRVO subsets in CFT changes (BRVO: P=.37; CRVO: P=.92) or change in BCVA (BRVO: P=.15; CRVO: P=.73). | Non-inferiority trial