# APPENDIX C PEER REVIEW COMMENTS AND AUTHOR RESPONSES

Question Text | Reviewer Number | Comment | Response
Are the objectives, scope, and methods for this review clearly described? | 1 | Yes | Noted, thank you.
Are the objectives, scope, and methods for this review clearly described? | 2 | Yes | Noted, thank you.
Are the objectives, scope, and methods for this review clearly described? | 3 | Yes | Noted, thank you.
Are the objectives, scope, and methods for this review clearly described? | 4 | Yes | Noted, thank you.
Are the objectives, scope, and methods for this review clearly described? | 5 | Yes | Noted, thank you.
Are the objectives, scope, and methods for this review clearly described? | 6 | Yes | Noted, thank you.
Is there any indication of bias in our synthesis of the evidence? | 1 | No | Noted, thank you.
Is there any indication of bias in our synthesis of the evidence? | 2 | No | Noted, thank you.
Is there any indication of bias in our synthesis of the evidence? | 3 | No | Noted, thank you.
Is there any indication of bias in our synthesis of the evidence? | 4 | No | Noted, thank you.
Is there any indication of bias in our synthesis of the evidence? | 5 | No | Noted, thank you.
Is there any indication of bias in our synthesis of the evidence? | 6 | No | Noted, thank you.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 1 | No | Noted, thank you.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 2 | No | Noted, thank you.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 3 | No | Noted, thank you.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 4 | No | Noted, thank you.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 5 | No | Noted, thank you.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 6 | No | Noted, thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | Excellent report I do have one concern about the DME results and the overall conclusion drawn. Page 32 lines 21-30 shows aflibercept to have statistically significant superiority to bevacizumab with mean improvement in vision at 12 months and still with increased improvement but not statistically significant at 24 months. This was also true for those with lower baseline BCVA for the aflibercept versus ranibizumab on page 33 lines 7-17. These were deemed "not clinically significant" presumably due to the lack of statistical significance at 24 months yet in both the mean visual acuity improvement was still higher in the aflibercept group. The final conclusions on page 69 should likely reflect this consistent superior improvement in VA at 12 months for aflibercept and improvement still yet not reaching statistical significance at 24 months. (This is stated in the table on page 62 line 56-60. | We have changed “clinically significant” to “clinically meaningful” throughout the report and have clarified our definition in the Data Synthesis section of the Methods. A clinically meaningful difference often has a greater threshold than statistical significance, as it is related to whether the difference is substantial and noticeable to the patient and relevant to clinical practice. We determined the clinically meaningful difference between drugs to be 5 or more ETDRS letters (i.e., one line) in consultation with our ophthalmologist authors. Since the difference in mean change in BCVA between aflibercept and bevacizumab (and aflibercept and ranibizumab on the following page) was less than 5 letters, this difference was not considered clinically meaningful. However, we revised the language in the paragraph about the subgroup with lower baseline BCVA, since the difference between groups was 6.5 letters. The final conclusion paragraph was also revised slightly to reflect the benefit seen with aflibercept in this study.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2 | In the comparative of cost-effectiveness section, although the literature only shows cost comparison data for multi-dosed vials of bevacizumab to the other two agents, the VA does not multi-dose the vial. Instead it is one 4cc vial per patient. Perhaps this should be mentioned either under this sub-section or in the Research Gaps/Future research section and that there is no cost comparative literature available when bevacizumab is not compounded. The cost-effectiveness will be reduced somewhat with this scenario but still likely superior to the two other agents. This could alternatively be mentioned in the Research Gaps/Future Research section on page 68. | This point was included in the Limitations section (second paragraph), but a sentence was added to the cost-effectiveness section (Key Question 3) as well. A clarification of this point was also added to the Executive Summary.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Findings form this analysis were not unexpected and confirms what is known about this topic | Noted.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | p.19 typo regarding bevacizumab dose; should read 1.25mg Trials used standard recommended doses of the drugs unless otherwise indicated (aflibercept 2.0 mg; bevacizumab 0.5 mg; ranibizumab 0.5 mg for AMD and BRVO/CRVO, and 0.3 mg for DME). | Thank you, this has been corrected.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | For the tables discussing costs, consider adding a footnote that pricing is based on wholesale costs and not VA costs | The term “compounded” as well as a footnote was added to the Summary of Evidence table when talking about the cost of bevacizumab to clarify that the cost was for compounded bevacizumab, which is not currently available at the VHA.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | Although not clearly defined in the key questions, the treatment burden for patients is an important consideration. For example, when comparing aflibercept to bevacizumab in the treatment of AMD, the report mentions the fact that in the fixed interval dosing phase of the VIEW trials, the visual results were comparable between aflibercept given bimonthly and ranibizumab given monthly, although this result is not used in the interpretation of the results. The fact that aflibercept can be given less frequently is an important consideration for both patient and physician. | Thank you, we agree that this is an important consideration. While we had already included a statement to this effect in the Limitations section, we have added some language to the Discussion section to help further address this issue. We also added a brief statement to the Results section about the comparable visual acuity results between these two groups, although the cost implications are unclear since this was not explored by the trial.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | The report mentions that in the DRCR.net protocol discussing the treatment of DME, the [*a priori*] subgroup analysis (emphasis mine) of patients with 20/50 or worse vision provides evidence that aflibercept results in better visual outcomes at 12 months than both bevacizumab and ranibizumab (although this improvement is lost at 24 months). This is an important point that should not be glossed over. The difference in visual outcomes in the study overall was driven by the patients with worse vision, at least in part because of a ceiling effect in the group with better starting vision (i.e. vision cannot be better than 20/20). A 7 letter difference between aflibercept and bevacizumab is indeed clinically significant (almost 2 lines of Snellen visual acuity). The conclusion that bevacizumab and aflibercept are equivalent in this context is erroneous. Even when considering the fact that the visual benefit decreases after 24 months, there is an important clinical benefit to having an additional year of better vision, even if this cannot be shown in terms of QALY or cost effectiveness. | Our definition of a clinical significant or meaningful difference in mean change in BCVA between drugs was clarified in the Methods section (5 or more ETDRS letters). We also revised this part in the Results to clarify the fact that aflibercept had a significant advantage over bevacizumab and ranibizumab at 12 months in the subgroup of patients with lower baseline BCVA. We added text to the Summary of Evidence table and Summary sections to clarify these findings as well.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | The report is comprehensive and includes all major RCTs on this topic. The report questions were adequately addressed. | Noted, thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 6 | We had three responses from field ophthalmologists. The points in all three comments are similar and captured in this comment: "The following finding for DME pts should be highlighted a bit more as an important finding: “These differences between aflibercept and both bevacizumab and ranibizumab were slightly more pronounced, but still clinically insignificant, in a subgroup analysis of patients with lower baseline BCVA.” | This statement was clarified in the text to highlight the fact that aflibercept had a clinically meaningful advantage over bevacizumab in this subgroup at 12 months. Similar statements have been added to summary statements throughout the draft.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 6 | Also, the following phrase needs to be clarified: “While few differences between agents were seen for most AEs, previous trials and systematic reviews have shown that patients treated with anti-VEGF agents are at higher risk for serious systemic AEs, including death and cerebrovascular accidents.” I assume the latter clause was from the systemic use NOT intraocular use. This needs to be made clearer. | In fact, this sentence is referencing data from systematic reviews comparing intravitreal anti-VEGF agents to sham/placebo or other treatments (such as laser therapy), which show an increased risk for some systemic AEs associated with intravitreal anti-VEGF. The wording in this sentence was revised to clarify this. A more detailed discussion of this evidence can be found in the last paragraph of the “Summary of the Evidence” section in the Discussion (immediately before the Limitations section).