# APPENDIX B QUALITY ASSESSMENT

## CRITERIA USED IN QUALITY ASSESSMENT

### Risk of Bias Assessment for Randomized Controlled Trials (RCTs): The Cochrane Collaboration Risk of Bias tool^18^

#### Overview

Domain | Description | Review authors' judgment
Sequence generation | Describe the method used to generate the allocation sequence in sufficient detail to allow an assessment of whether it should produce comparable groups. | Was the allocation sequence adequately generated?
Allocation concealment | Describe the method used to conceal the allocation sequence in sufficient detail to determine whether intervention allocations could have been foreseen in advance of or during enrollment. | Was allocation adequately concealed?
Blinding of participants, personnel and outcome assessors Assessments should be made for each main outcome (or class of outcomes). | Describe all measures used, if any, to blind study participants and personnel from knowledge of which intervention a participant received. Provide any information relating to whether the intended blinding was effective. | Was knowledge of the allocated intervention adequately prevented during the study?
Incomplete outcome data Assessments should be made for each main outcome (or class of outcomes). | Describe the completeness of outcome data for each main outcome, including attrition and exclusions from the analysis. State whether attrition and exclusions were reported, the numbers in each intervention group (compared with total randomized participants), reasons for attrition/exclusions where reported, and any re-inclusions in analyses performed by the review authors. | Were incomplete outcome data adequately addressed?
Selective outcome reporting | State how the possibility of selective outcome reporting was examined by the review authors, and what was found. | Are reports of the study free of suggestion of selective outcome reporting?
Other sources of bias | State any important concerns about bias not addressed in the other domains in the tool. If particular questions/entries were pre-specified in the review's protocol, responses should be provided for each question/entry. | Was the study apparently free of other problems that could put it at a high risk of bias?

#### Specific Criteria Details for Judging Risk of Bias by Domain

SEQUENCE GENERATION Was the allocation sequence adequately generated? [Short form: Adequate sequence generation?]
Criteria for a judgment of ‘YES’ (ie, low risk of bias) | The investigators describe a random component in the sequence generation process such as:; ▪ Referring to a random number table; using a computer random number generator; coin tossing; shuffling cards or envelopes; throwing dice; drawing of lots; minimization.*; *Minimization may be implemented without a random element, and this is considered to be equivalent to being random.
Criteria for the judgment of ‘NO’ (ie, high risk of bias) | The investigators describe a non-random component in the sequence generation process. Usually, the description would involve some systematic, non-random approach, for example:; ▪ Sequence generated by odd or even date of birth;; ▪ Sequence generated by some rule based on date (or day) of admission;; ▪ Sequence generated by some rule based on hospital or clinic record number.; Other non-random approaches happen much less frequently than the systematic approaches mentioned above and tend to be obvious. They usually involve judgment or some method of non-random categorization of participants, for example:; ▪ Allocation by judgment of the clinician;; ▪ Allocation by preference of the participant;; ▪ Allocation based on the results of a laboratory test or a series of tests;; ▪ Allocation by availability of the intervention.
Criteria for the judgment of ‘UNCLEAR’ (ie, uncertain risk of bias) | Insufficient information about the sequence generation process to permit judgment of ‘Yes’ or ‘No’.
ALLOCATION CONCEALMENT Was allocation adequately concealed? [Short form: Allocation concealment?]
Criteria for a judgment of ‘YES’ (ie, low risk of bias) | Participants and investigators enrolling participants could not foresee assignment because one of the following, or an equivalent method, was used to conceal allocation:; ▪ Central allocation (including telephone, web-based, and pharmacy-controlled randomization);; ▪ Sequentially numbered drug containers of identical appearance;; ▪ Sequentially numbered, opaque, sealed envelopes.
Criteria for the judgment of ‘NO’ (ie, high risk of bias) | Participants or investigators enrolling participants could possibly foresee assignments and thus introduce selection bias, such as allocation based on:; ▪ Using an open random allocation schedule (eg, a list of random numbers);; ▪ Assignment envelopes were used without appropriate safeguards (eg, if envelopes were unsealed or non-opaque or not sequentially numbered);; ▪ Alternation or rotation;; ▪ Date of birth;; ▪ Case record number;; ▪ Any other explicitly unconcealed procedure.
Criteria for the judgment of ‘UNCLEAR’ (ie, uncertain risk of bias) | Insufficient information to permit judgment of ‘Yes’ or ‘No’. This is usually the case if the method of concealment is not described or not described in sufficient detail to allow a definite judgment; for example, if the use of assignment envelopes is described, but it remains unclear whether envelopes were sequentially numbered, opaque and sealed.
BLINDING OF PARTICIPANTS, PERSONNEL AND OUTCOME ASSESSORS Was knowledge of the allocated interventions adequately prevented during the study? [Short form: Blinding?]
Criteria for a judgment of ‘YES’ (ie, low risk of bias) | Any one of the following:; ▪ No blinding, but the review authors judge that the outcome and the outcome measurement are not likely to be influenced by lack of blinding;; ▪ Blinding of participants and key study personnel ensured, and unlikely that the blinding could have been broken;; ▪ Either participants or some key study personnel were not blinded, but outcome assessment was blinded and the non-blinding of others unlikely to introduce bias.
Criteria for the judgment of ‘NO’ (ie, high risk of bias) | Any one of the following:; ▪ No blinding or incomplete blinding, and the outcome or outcome measurement is likely to be influenced by lack of blinding;; ▪ Blinding of key study participants and personnel attempted, but likely that the blinding could have been broken;; ▪ Either participants or some key study personnel were not blinded, and the non-blinding of others likely to introduce bias.
Criteria for the judgment of ‘UNCLEAR’ (ie, uncertain risk of bias) | Any one of the following:; ▪ Insufficient information to permit judgment of ‘Yes’ or ‘No’;; ▪ The study did not address this outcome.
INCOMPLETE OUTCOME DATA Were incomplete outcome data adequately addressed? [Short form: Incomplete outcome data addressed?]
Criteria for a judgment of ‘YES’ (ie, low risk of bias) | Any one of the following:; ▪ No missing outcome data;; ▪ Reasons for missing outcome data unlikely to be related to true outcome (for survival data, censoring unlikely to be introducing bias);; ▪ Missing outcome data balanced in numbers across intervention groups, with similar reasons for missing data across groups;; ▪ For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk not enough to have a clinically relevant impact on the intervention effect estimate;; ▪ For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes not enough to have a clinically relevant impact on observed effect size;; ▪ Missing data have been imputed using appropriate methods.
Criteria for the judgment of ‘NO’ (ie, high risk of bias) | Any one of the following:; ▪ Reason for missing outcome data likely to be related to true outcome, with either imbalance in numbers or reasons for missing data across intervention groups;; ▪ For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk enough to induce clinically relevant bias in intervention effect estimate;; ▪ For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes enough to induce clinically relevant bias in observed effect size;; ▪ ‘As-treated’ analysis done with substantial departure of the intervention received from that assigned at randomization;; ▪ Potentially inappropriate application of simple imputation.
Criteria for the judgment of ‘UNCLEAR’ (ie, uncertain risk of bias) | Any one of the following:; ▪ Insufficient reporting of attrition/exclusions to permit judgment of ‘Yes’ or ‘No’ (eg, number randomized not stated, no reasons for missing data provided);; ▪ The study did not address this outcome.
SELECTIVE OUTCOME REPORTING Are reports of the study free of suggestion of selective outcome reporting? [Short form: Free of selective reporting?]
Criteria for a judgment of ‘YES’ (ie, low risk of bias) | Any of the following:; ▪ The study protocol is available and all of the study's pre-specified (primary and secondary) outcomes that are of interest in the review have been reported in the pre-specified way;; ▪ The study protocol is not available but it is clear that the published reports include all expected outcomes, including those that were pre-specified (convincing text of this nature may be uncommon).
Criteria for the judgment of ‘NO’ (ie, high risk of bias) | Any one of the following:; ▪ Not all of the study's pre-specified primary outcomes have been reported;; ▪ One or more primary outcomes is reported using measurements, analysis methods or subsets of the data (eg, subscales) that were not pre-specified;; ▪ One or more reported primary outcomes were not pre-specified (unless clear justification for their reporting is provided, such as an unexpected adverse effect);; ▪ One or more outcomes of interest in the review are reported incompletely so that they cannot be entered in a meta-analysis;; ▪ The study report fails to include results for a key outcome that would be expected to have been reported for such a study.
Criteria for the judgment of ‘UNCLEAR’ (ie, uncertain risk of bias) | Insufficient information to permit judgment of ‘Yes’ or ‘No’. It is likely that the majority of studies will fall into this category.
OTHER POTENTIAL THREATS TO VALIDITY Was the study apparently free of other problems that could put it at a risk of bias? [Short form: Free of other bias?]
Criteria for a judgment of ‘YES’ (ie, low risk of bias) | The study appears to be free of other sources of bias.
Criteria for the judgment of ‘NO’ (ie, high risk of bias) | There is at least one important risk of bias. For example, the study:; ▪ Had a potential source of bias related to the specific study design used; or; ▪ Stopped early due to some data-dependent process (including a formal-stopping rule); or; ▪ Had extreme baseline imbalance; or; ▪ Has been claimed to have been fraudulent; or; ▪ Had some other problem.
Criteria for the judgment of ‘UNCLEAR’ (ie, uncertain risk of bias) | There may be a risk of bias, but there is either:; ▪ Insufficient information to assess whether an important risk of bias exists; or; ▪ Insufficient rationale or evidence that an identified problem will introduce bias.

## QUALITY ASSESSMENT OF INCLUDED STUDIES

Author, Year; Trial name | Sequence generation: Was the allocation sequence adequately generated? | Allocation concealment: Was allocation adequately concealed? | Blinding: Was knowledge of the allocated intervention adequately prevented during the study? | Incomplete outcome data: Were incomplete outcome data adequately addressed? | Selective outcome reporting: Are reports of the study free of suggestion of selective outcome reporting? | Other sources of bias: Was the study apparently free of other problems that could put it at a high risk of bias? | Overall assessment of potential for bias: Low/Unclear/High
Choroidal Neovascularization Secondary to Age-Related Macular Degeneration (AMD)Trials
Biswas 2011^33^ | Yes: random number tables. | Unclear: blinding of random number table allocation not reported. | Assessors: Yes. Participants: Unclear. Providers: Yes. | Unclear: loss to follow-up acceptable (16.6% and 10%), but reasons were not reported. Analyses were not ITT. | No: protocol or registration number not provided. Definitions of “minor complications” not reported. | Unclear: effectiveness of randomization is unclear as more men were randomized to bevacizumab (56%) than to ranibizumab (41%). | Unclear
BRAMD; Schauwvlieghe 2016^45^ | Yes: computer-generated using TENALEA Clinical Trial Data Management System and stratified by center, BCVA in study eye and fellow eye. | Yes: upon randomization an automatized email notification containing the allocation result was sent to the site's pharmacy. | Assessors: Yes. Participants and providers: Yes. | Yes: ITT analyses reported; acceptable and equal loss to follow-up (19.0%). Missing values imputed using last observation carried forward (LOCF) approach. BCVA at the moment of switch was used for patients who were switched to the other treatment due to non-response. | Unclear: all outcomes pre-specified in the protocol are reported. However, reporting of adverse events was not entirely clear (not separated by ocular vs systemic, just reports “occurrence of serious adverse events”) and not all P-values reported. | Yes | Low
CATT; Martin 2012^41,42^ | Yes: computer-generated randomization schedules using a web-based data management system, stratified according to clinical center with the use of a permuted-block method with a randomly chosen block size. | Yes: allocated using a web-based data management system. | Assessors: Yes Participants: No (“Patients were not informed of their drug assignment; however, insurance and billing documents specified ranibizumab but not study-supplied bevacizumab. Therefore, patients may have learned or deduced their assigned drug from these financial documents.”) Providers: Yes (although not masked to dosing schedule, monthly or PRN). | Unclear: methods reported using ITT analyses but 1-year outcomes did not include 103 patients (8.6%) lost to follow-up (due to missing data). Three alternative approaches for handling missing data from the 52-week examination were performed as sensitivity analyses. | Yes: all outcomes pre-specified in the protocol are reported. | Yes | Low
GEFAL; Kodjikian 2013^34^ | Unclear: randomized using “pre-established lists.” | Yes: allocation completed by local hospital pharmacies. | Assessors: Yes. Participants and providers: Yes. | Unclear: 25% lost to follow-up and reasons were reported. Primary analysis was per protocol but ITT analysis also reported, although 97 (19.3%) patients were not included. | Unclear: specific secondary outcomes reported in publication were not reported in ClinicalTrials.gov protocol, and “time before re-injection” from the protocol was not reported in publication. | Unclear: some baseline differences in medical history and total choroidal neovascularization area; however, unlikely to have affected outcomes of interest. | Unclear
IVAN; Chakravarthy 2013^27,37,38^ | Yes: computer-generated by a third party in blocks and stratified by center. | Yes: concealed using an internet-based system provided by Sealed Envelope Ltd. | Assessors: Yes. Participants and providers: Yes. | Unclear: 18 patients (9 in each group) were excluded from the analyses because they were randomized in error or were not treated, leaving 610 patients who received ≥1 injection. One-year results not reported for 49 (8%) participants and 2-year results not reported for 85 (13.9%). Reasons for withdrawals and missing data thoroughly reported. Multiple imputation using a series of chained regression equations was used to impute missing data. | Yes: all outcomes pre-specified in the protocol are reported. | Yes | Low
LUCAS; Berg 2015^39,40^ | Yes: computer-generated with the use of the block method and stratified by center. | Yes: randomization completed by a third party. | Assessors: Yes Participants and providers: Yes | Yes: ITT and per-protocol analyses reported. Attrition was acceptable and even (15%). | Yes: protocol published on ClinicalTrials.gov, all outcomes pre-specified are reported. | Unclear: the patients in the ranibizumab group more often had a history of myocardial infarctions than the patients in the bevacizumab group; increased cardiac events in ranibizumab occurred during trial. | Low
MANTA; Krebs 2013^35^ | Unclear: “Randomisation was stratified according to the clinical centre using a permuted block method with a fixed block size of 20,” but process of selecting the blocks was not specified. | Yes: central allocation by members of the Department of Clinical Pharmacology at Medical University of Vienna, which was otherwise not involved in the study. | Assessors: Yes. Participants and providers: Yes (injecting physician not blinded, but was not involved in the collection of data). | Unclear: Efficacy analysis was ITT; last observation carried forward method used to handle missing data for 69 (21.4%) patients. Loss to follow-up information not reported. | Unclear: Data for some measures had to be estimated from graphs. | Yes | Unclear
Scholler 2014^29^ | Yes: computer-generated list of random numbers. | Unclear: not reported. | Assessors: Unclear (not reported). Participants and providers: Unclear (not reported). | No: method of handling incomplete data not reported, unclear whether ITT analysis conducted (reports exclusion of 9 patients, but not whether they were included in analyses), uneven number of exclusions between groups. | No: registration numbers provided appear to be for a different trial. Did not provide mean change calculations for BCVA or anatomic outcomes. | No: Small study and power calculation not reported. Funding source not reported. | High
Subramanian 2010^26^ | Unclear: “all subjects were assigned a study number.” | Yes: central allocation by research pharmacist. | Assessors: Yes. Participants and providers: Yes. | No: ITT analysis not performed; uneven loss to follow-up (25% vs 13%). | No: adverse events only reported for patients completing 1-year follow-up visit. Data on minor adverse events not reported. | No: not powered to detect differences (original goal sample size was calculated to be 135, while actual enrollment was only 28, with only 22 analyzed). | High
VIEW 1; Heier 2012^43^ | Unclear: “Consecutively enrolled patients were assigned to treatment groups on the basis of a predetermined central randomization scheme with balanced allocation,” but unclear what the “randomization scheme” entailed. | Yes: central allocation by an interactive voice response system. | Assessors: Yes Participants: Yes Providers: No, an unmasked investigator performed the injection, but this was unlikely to have introduced bias | Yes: acceptable and equal loss to follow-up (7.1%); missing values imputed using last observation carried forward (LOCF) approach. “Full Analysis set” only included randomized patients who received any study medication and had a baseline and at least 1 post-baseline BCVA assessment; however, 99.4% of randomized patients were included in this analysis. | Unclear: all outcomes pre-specified in ClinicalTrials.gov protocol; however, confidence intervals or P-values not reported for all outcomes. | Unclear: funded by manufacturer. | Low
VIEW 2; Heier 2012^43^ | Unclear: “Consecutively enrolled patients were assigned to treatment groups on the basis of a predetermined central randomization scheme with balanced allocation,” but unclear what the “randomization scheme” entailed. | Yes: allocation managed by an interactive voice response system | Assessors: Yes Participants: Yes Providers: No, an unmasked investigator performed the injection, but this was unlikely to have introduced bias | Yes: acceptable and equal loss to follow-up (10.2%); missing values imputed using last observation carried forward (LOCF) approach. “Full Analysis set” only included randomized patients who received any study medication and had a baseline and at least 1 post-baseline BCVA assessment; however, 96.9% of randomized patients were included in this analysis. | Unclear: all outcomes pre-specified in ClinicalTrials.gov protocol; however, confidence intervals or P-values not reported for all outcomes. | Unclear: funded by manufacturer. | Low
Diabetic Macular Edema (DME) Trials
DRCR.net (Protocol T); Wells 2016^46,47^ | Yes: performed at the DRCR.net study website (computer-generated) in permuted blocks and with stratification according to study site and visual acuity in the study eye. | Yes: central randomization at the DRCR.net study website. | Assessors: Yes. Participants and providers: Yes. | Yes: 7% lost to follow-up (similar between groups). Primary analysis used ITT; used Markov chain Monte Carlo method of multiple imputation to impute missing data (sensitivity analyses with different approaches for handling missing data produced similar results). There was no imputation for missing data in secondary analyses. | Yes: all outcomes pre-specified in the protocol are reported. | Yes | Low
Ekinci 2014^30^ | Unclear: randomization method not reported. | Unclear: allocation concealment method not reported. | Assessors: Unclear, not reported. Participants and providers: Unclear, not reported. | No: excluded 15 participants after randomization due to adverse events; not reported by randomization group. | Unclear: protocol or registration number not provided. | Yes: either made an error reporting ranibizumab dose, or used an atypical dose (one tenth of typical dose). | High
Nepomuceno 2013^31^ | Yes: computer-generated sequence. However, if both eyes were eligible for treatment, one eye received randomized treatment and the contralateral eye received the other anti-VEGF agent. | Unclear: not reported. | Assessors: Yes. Participants and providers: Yes. | Unclear: incomplete data not reported. Analyses were not ITT. | No: change in BCVA was listed as the primary outcome but was not clearly reported for week 48. Outcomes were reported based on at what timepoint there were significant differences. | No: sample size calculation was based on power to detect a difference of 50um between groups in central subfield thickness, and might have been underpowered to detect clinically meaningful differences in BCVA. Also, since 15 patients were treated with both treatments (one in each eye), there was possible crossover that could obscure differences in effects between the drugs. | High
Macular Edema due to Central Retinal Vein Occlusion (CRVO) or Branch Retinal Vein Occlusion (BRVO) Trials
CRAVE; Rajagopal 2015^32^ | No: reported using centralized, computer-generated random table for assignments, but an additional 9 patients included in the study who were not randomized to treatment due to financial hardship and were instead assigned to the bevacizumab group. | Unclear: states that “assistance programs were used to defray any financial hardship, but if it could not be eliminated, then the patient was assigned to the bevacizumab arm,” which could have introduced bias in allocation. | No: patients, technicians, and examining physicians were not masked to treatment. | Unclear: ITT using LOCF was used for analyses. 25% loss-to-follow-up, but reasons were not reported. | Yes: protocol published on ClinicalTrials.gov, all outcomes pre-specified are reported. | Unclear: power of the study was calculated for anatomical change (their primary outcome) of 50 μm, not BCVA, so it is unknown whether the study was powered to detect differences in BCVA. Original enrollment planned for 150 patients, but only 98 were randomized. | High
MARVEL; Narayanan 2015^36^ | Unclear: “randomised...in a 1:1 ratio in block sizes of 6,” but process of selecting the blocks was not specified. | Unclear: not reported. | Assessors: Unclear Participants: Unclear Providers: Yes Study is described as “double-masked” but does not specify blinding of outcome assessors (other than at baseline) or patients. | Yes: ITT analyses using LOCF to impute for missing data; 90% completed the study (reasons for not completing NR). | Unclear: a trial registration number was provided but the protocol was unavailable. | Effectiveness of randomization is unclear: P-values not reported for baseline characteristics, and the ranibizumab group had a much higher proportion of females (60% vs 32%) | Unclear