# APPENDIX A SEARCH STRATEGIES

## SEARCH STRATEGY OVERVIEW

Databases Searched:

- Ovid Medline
- PubMed
- Elsevier Embase (http://Embase.com)
- Ovid EBM Reviews (Cochrane Central Register of Controlled Trials; Cochrane Database of Systematic Reviews; Health Technology Assessment; NHS Economic Evaluation Database)

Clinical Trial Registries:

- ClinicalTrials.gov (https://clinicaltrials.gov/ct2/search/advanced)
- WHO ICTRP (http://apps.who.int/trialsearch/)
- ISRCTN Registry (http://www.isrctn.com/)

Regulatory Agencies:

- FDA
- EMA

Conference Proceedings:

- Association for Research in Vision and Ophthalmology
- American Academy of Ophthalmology
- American Society of Retina Specialists
- COS Conference Papers Index

Scientific Information Packet Requests:

- LUCENTIS ® (ranibizumab); Genentech (Novartis)
- AVASTIN ® (bevacizumab); Genentech (Roche)
- EYLEA® (aflibercept); Regeneron Pharmaceuticals, Inc.

Future Research:

- NIH Reporter (https://projectreporter.nih.gov/reporter.cfm)
- AHRQ Gold (http://gold.ahrq.gov/projectsearch/)

## ELECTRONIC SEARCH STRATEGIES

Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) 1946 to November Week 3 2015, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations December 11, 2015

Date Searched: December 11, 2015

1 | exp Angiogenesis Inhibitors/ | 38860
2 | Antibodies, Monoclonal, Humanized/ | 30005
3 | Endothelial Growth Factors/ | 8163
4 | exp Vascular Endothelial Growth Factors/ | 42393
5 | ((endothelial adj2 growth adj2 factor*) or VEGF or VEGF-A or ((anti* or inhibit*) adj2 VEGF*) or antiVEGF* or anti-VEGF* or VEGF TRAP* or ((anti* or inhibit*) adj2 angiogen*)).tw. | 72844
6 | (aflibercept* or EYLEA* or bevacizumab* or Avastin* or ranibizumab* or Lucentis*).tw. | 12368
7 | or/1-6 | 129921
8 | Visual acuity/ | 62548
9 | (visual* or vision or ETDRS or BCVA).tw. | 511121
10 | or/8-9 | 530892
11 | Diabetic Retinopathy/ | 20770
12 | Glaucoma, Neovascular/ | 710
13 | Macular Degeneration/ | 12937
14 | Macular Edema/ | 5087
15 | Wet Macular Degeneration/ | 956
16 | Choroidal Neovascularization/ | 4602
17 | Vitreous Hemorrhage/ | 1734
18 | Retinal Vein Occlusion/ | 3355
19 | ((macula* adj3 (edema* or oedema* or degenerat*)) or (retin* adj3 (angiogenesis* or vein* or occlu* or obstruct* or clos* or stricture* or steno* or block* or embolism*)) or (proliferat* adj3 retinopath*) or (glaucoma* adj4 (neovascular* or haemorrhag* or hemorrhag* or thrombo* or congestive or rubeot*)) or (neovascular* adj2 (retinopath* or retinal* or intraocular* or intravitreal* or glaucoma* or choroidal)) or (vitreous adj2 (haemorrhag* or hemorrhag*)) or new blood vessel* or retinopath* or maculopath* or CME or CSME or CMO or CSMO or DMO or DME or NVG or NVI or BRVO or RVO or AMD or WAMD or CNV).tw. | 83310
20 | or/11-19 | 93025
21 | and/7,10,20 | 4393
22 | remove duplicates from 21 | 4166
23 | limit 22 to (case reports or comment or editorial or letter or news) | 689
24 | 22 not 23 (GENERAL SEARCH RESULTS) | 3477
25 | 7 and 20 | 10749
26 | (ae or co or de).fs. | 5215408
27 | (harm or harms or harmful or safe or safety or side effect* or undesirable effect* or treatment emergent or tolerability or toxic* or adrs or (adverse adj2 (effect or effects or reaction or reactions or event or events or outcome or outcomes))).tw. | 1331876
28 | or/26-27 | 5972462
29 | 25 and 28 | 5489
30 | limit 29 to (meta analysis or systematic reviews) | 183
31 | 30 not 24 (ADVERSE EVENTS/HARMS SEARCH RESULTS) | 65

Note: Bevacizumab/ and Ranibizumab/ are new MeSH Terms as of 2016, but currently do not have any results linked to the subject terms, and therefore these were not used in the search. Future search strategies however should include these MeSH terms.

### PubMed

Date Searched: February 4, 2016

#14 | Search (#13 OR #7) (ALL SEARCH RESULTS) | 450 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#12 NOT #7) (ADVERSE EVENTS/HARMS SEARCH RESULTS) | 34 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#12 | Search (#11 AND english [language]) | 148 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 AND #5) | 154 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 AND #8) | 795 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (harm[Title/Abstract] OR harms[Title/Abstract] OR harmful[Title/Abstract] OR safe[Title/Abstract] OR safety[Title/Abstract] OR side effects[Title/Abstract] OR undesirable effect*[Title/Abstract] OR treatment emergent[Title/Abstract] OR tolerability[Title/Abstract] OR toxic*[Title/Abstract] OR adrs[Title/Abstract] OR adverse effect[Title/Abstract] OR adverse effects[Title/Abstract] OR adverse reaction[Title/Abstract] OR adverse reactions[Title/Abstract] OR adverse event[Title/Abstract] OR adverse events[Title/Abstract] OR adverse outcome[Title/Abstract] OR adverse outcomes[Title/Abstract]) | 1350876 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 AND #3) | 2656 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#6 AND english [language]) (GENERAL SEARCH RESULTS) | 416 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#4 AND #5) | 429 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((publisher [sb] NOT pubstatusnihms NOT pubstatuspmcsd NOT pmcbook) OR inprocess [sb] OR pubmednotmedline [sb] OR pmcbook OR (publisher [sb] AND (pubstatusnihms OR pubstatuspmcsd))) | 2783356 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 AND #2 AND #3) | 1826 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (((macula*[Title/Abstract] AND (edema*[Title/Abstract] OR oedema*[Title/Abstract] OR degenerat*))[Title/Abstract] OR (retin*[Title/Abstract] AND (angiogenesis*[Title/Abstract] OR vein*[Title/Abstract] OR occlu*[Title/Abstract] OR obstruct*[Title/Abstract] OR clos*[Title/Abstract] OR stricture*[Title/Abstract] OR steno*[Title/Abstract] OR block*[Title/Abstract] OR embolism*))[Title/Abstract] OR (proliferat*[Title/Abstract] AND retinopath*)[Title/Abstract] OR (glaucoma*[Title/Abstract] AND (neovascular*[Title/Abstract] OR haemorrhag*[Title/Abstract] OR hemorrhag*[Title/Abstract] OR thrombo*[Title/Abstract] OR congestive[Title/Abstract] OR rubeot*))[Title/Abstract] OR (neovascular*[Title/Abstract] AND (retinopath*[Title/Abstract] OR retinal*[Title/Abstract] OR intraocular*[Title/Abstract] OR intravitreal*[Title/Abstract] OR glaucoma*[Title/Abstract] OR choroidal))[Title/Abstract] OR (vitreous[Title/Abstract] AND (haemorrhag*[Title/Abstract] OR hemorrhag*))[Title/Abstract] OR new blood vessel*[Title/Abstract] OR retinopath*[Title/Abstract] OR maculopath*[Title/Abstract] OR CME[Title/Abstract] OR CSME[Title/Abstract] OR CMO[Title/Abstract] OR CSMO[Title/Abstract] OR DMO[Title/Abstract] OR DME[Title/Abstract] OR NVG[Title/Abstract] OR NVI[Title/Abstract] OR BRVO[Title/Abstract] OR RVO[Title/Abstract] OR AMD[Title/Abstract] OR WAMD[Title/Abstract] OR CNV[Title/Abstract])) | 59871 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((visual*[Title/Abstract] or vision[Title/Abstract] or ETDRS[Title/Abstract] or BCVA[Title/Abstract])) | 515210 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((aflibercept*[Title/Abstract] OR EYLEA*[Title/Abstract] OR bevacizumab*[Title/Abstract] OR Avastin*[Title/Abstract] OR ranibizumab*[Title/Abstract] OR Lucentis*[Title/ Abstract])) | 12614 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)

### Elsevier EMBASE.COM

Date Searched: February 3, 2016

#34 | #33 NOT #28 (ADVERSE EVENTS/HARMS SEARCH RESULTS) | 99
#33 | #30 OR #31 AND ([systematic review]/lim OR [meta analysis]/lim) | 202
#32 | #30 OR #31 | 6,445
#31 | #29 AND (harm:ab,ti OR harms:ab,ti OR harmful:ab,ti OR safe:ab,ti OR safety:ab,ti OR side:ab,ti AND effect*:ab,ti OR undesirable:ab,ti AND effect*:ab,ti OR treatment:ab,ti AND emergent:ab,ti OR tolerability:ab,ti OR toxic*:ab,ti OR adrs:ab,ti OR (adverse NEAR/2 (effect OR effects OR reaction OR reactions OR event OR events OR outcome OR outcomes)):ab,ti) | 1,636
#30 | #29 AND (‘adverse drug reaction’/lnk OR ‘complication’/lnk OR ‘side effect’/lnk) | 5,716
#29 | #10 AND #23 | 18,185
#28 | #25 NOT (#26 OR #27) (GENERAL SEARCH RESULTS) | 5,131
#27 | #25 AND ([editorial]/lim OR [letter]/lim) 420 | 420
#26 | #25 AND ‘case report’/de 910 | 910
#25 | #10 AND #13 AND #23 AND [embase]/lim 6,298 | 6,298
#24 | #10 AND #13 AND #23 6,815 | 6,815
#23 | #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 127,711 | 127,711
#22 | (macula* NEAR/3 (edema* OR oedema* OR degenerat*)):ab,ti OR (retin* NEAR/3 (angiogenesis* OR vein* OR occlu* OR obstruct* OR clos* OR stricture* OR steno* OR block* OR embolism*)):ab,ti OR (proliferat* NEAR/3 retinopath*):ab,ti OR (glaucoma* NEAR/4 (neovascular* OR haemorrhag* OR hemorrhag* OR thrombo* OR congestive OR rubeot*)):ab,ti OR (neovascular* NEAR/2 (retinopath* OR retinal* OR intraocular* OR intravitreal* OR glaucoma* OR choroidal)):ab,ti OR (vitreous NEAR/2 (haemorrhag* OR hemorrhag*)):ab,ti OR new:ab,ti AND blood:ab,ti AND vessel*:ab,ti OR retinopath*:ab,ti OR maculopath*:ab,ti OR cme:ab,ti OR csme:ab,ti OR cmo:ab,ti OR csmo:ab,ti OR dmo:ab,ti OR dme:ab,ti OR nvg:ab,ti OR nvi:ab,ti OR brvo:ab,ti OR rvo:ab,ti OR amd:ab,ti OR wamd:ab,ti OR cnv:ab,ti 91,083 | 91,083
#21 | ‘retina vein occlusion’/exp 6,089 | 6,089
#20 | ‘vitreous hemorrhage’/de 4,949 | 4,949
#19 | ‘subretinal neovascularization’/de 7,248 | 7,248
#18 | ‘wet macular degeneration’/de | 520
#17 | ‘macular edema’/exp | 12,382
#16 | ‘macular degeneration’/exp | 22,598
#15 | ‘neovascular glaucoma’/de | 1,724
#14 | ‘diabetic retinopathy’/exp | 30,963
#13 | #11 OR #12 | 657,503
#12 | visual*:ab,ti OR vision:ab,ti OR etdrs:ab,ti OR bcva:ab,ti | 631,128
#11 | ‘visual acuity’/de | 85,654
#10 | #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 | 528,436
#9 | aflibercept*:ab,ti OR eylea*:ab,ti OR ‘trap eye’:ab,ti OR bevacizumab*:ab,ti OR avastin*:ab,ti OR ranibizumab*:ab,ti OR lucentis*:ab,ti | 20,686
#8 | ‘ranibizumab’/de | 5,100
#7 | ‘bevacizumab’/de | 38,277
#6 | ‘aflibercept’/de | 2,484
#5 | (endothelial NEAR/2 growth NEAR/2 factor*):ab,ti OR ((anti* OR inhibit*) NEAR/2 vegf*):ab,ti OR antivegf*:ab,ti OR ‘anti vegf*’:ab,ti OR (vegf NEAR/2 trap*):ab,ti OR ((anti* OR inhibit*) NEAR/2 angiogen*):ab,ti | 79,695
#4 | ‘vasculotropin’/de | 77,826
#3 | ‘endothelial cell growth factor’/de | 2,066
#2 | ‘monoclonal antibody’/exp | 391,126
#1 | ‘angiogenesis inhibitor’/exp | 102,979

### Ovid EBM Reviews

- Cochrane Central Register of Controlled Trials December 2015
- Cochrane Database of Systematic Reviews 2005 to January 29, 2016
- Database of Abstracts of Reviews of Effects 2nd Quarter 2015
- Health Technology Assessment 1st Quarter 2016
- NHS Economic Evaluation Database 1st Quarter 2016

Date Searched: February 4, 2016

1 | (aflibercept* or EYLEA* or bevacizumab* or Avastin* or ranibizumab* or Lucentis*).tw. | 2147
2 | (visual* or vision or ETDRS or BCVA).tw. | 46966
3 | ((macula* adj3 (edema* or oedema* or degenerat*)) or (retin* adj3 (angiogenesis* or vein* or occlu* or obstruct* or clos* or stricture* or steno* or block* or embolism*)) or (proliferat* adj3 retinopath*) or (glaucoma* adj4 (neovascular* or haemorrhag* or hemorrhag* or thrombo* or congestive or rubeot*)) or (neovascular* adj2 (retinopath* or retinal* or intraocular* or intravitreal* or glaucoma* or choroidal)) or (vitreous adj2 (haemorrhag* or hemorrhag*)) or new blood vessel* or retinopath* or maculopath* or CME or CSME or CMO or CSMO or DMO or DME or NVG or NVI or BRVO or RVO or AMD or WAMD or CNV).tw. | 6283
4 | and/1-3 | 570
5 | limit 4 to english language [Limit not valid in CDSR,DARE; records were retained] | 434
6 | and/1,3 | 749
7 | (harm or harms or harmful or safe or safety or side effect* or undesirable effect* or treatment emergent or tolerability or toxic* or adrs or (adverse adj2 (effect or effects or reaction or reactions or event or events or outcome or outcomes))).tw. | 194241
8 | and/6-7 | 311
9 | limit 8 to english language [Limit not valid in CDSR,DARE; records were retained] | 238
10 | limit 9 to full systematic reviews [Limit not valid in CCTR,DARE,CLHTA,CLEED; records were retained] | 226
11 | limit 10 to new reviews [Limit not valid in CCTR; records were retained] | 193
12 | limit 11 to recently updated reviews [Limit not valid in CCTR,DARE,CLHTA,CLEED; records were retained] | 174
13 | 12 not 5 | 21
14 | 13 or 5 | 455

### ClinicalTrials.gov

Date Searched: February 7, 2016

11 studies found for: Interventional Studies \| (aflibercept OR EYLEA OR trap-eye) and (bevacizumab OR Avastin) \| Adult, Senior \| Phase 3, 4 18 studies found for: Interventional Studies \| (aflibercept OR EYLEA OR trap-eye) and (ranibizumab OR Lucentis) \| Adult, Senior \| Phase 3, 4 27 studies found for: Interventional Studies \| (bevacizumab OR Avastin) and (ranibizumab OR Lucentis) \| Adult, Senior \| Phase 3, 4

### WHO ICTRP

Date Searched: February 2, 2016

1 | diabetic retinopath^*^ OR neovascular^*^ glaucoma OR AMD OR macular degeneration OR macular edema^*^ OR macular oedema^*^ OR vitreous hemorrhag^*^ OR vitreous haemorrhag^*^ OR choroidal neovascularization^*^ OR choroidal neovascularisation^*^ OR retinal vein occlusion^*^
2 | aflibercept OR EYLEA OR trap-eye OR bevacizumab OR Avastin OR ranibizumab OR Lucentis
3 | 1 AND 2 = 1084 records for 739 trials^*^

* Of 1084 records, 797 were ClinicalTrials.gov records which were removed from the total number of results, and 287 records were downloaded

### ISRCTN Registry

Date Searched: February 2, 2016

Text Search | aflibercept OR EYLEA OR trap-eye OR bevacizumab OR Avastin OR ranibizumab OR Lucentis | 61 results
Limit | Eye Diseases | 22 results^*^

* Of 22 result records, 19 were on specified conditions and downloaded

### Association for Research in Vision and Ophthalmology (-2009 captured in COS Conference Papers Index)

Date Searched: February 8, 2016

2009-present conference content unavailable on Association website.

### American Academy of Ophthalmology (-2007 captured in COS Conference Papers Index)

Date Searched: February 8, 2016

aflibercept^*^ OR EYLEA^*^ OR bevacizumab^*^ OR Avastin^*^ OR ranibizumab^*^ OR Lucentis^*^ = 0 results^*^

* Website conference database was not working correctly on search day, unable to view specific conference programs.

### American Society of Retina Specialists

Date Searched: February 2, 2016

Past conference content unavailable on Society website and conference paper indices.

### COS Conference Papers Index

Date Searched: February 8, 2016

(all(aflibercept*) OR all(EYLEA*) OR all(bevacizumab*) OR all(Avastin*) OR all(ranibizumab*) OR all(Lucentis*)) AND (all(Diabetic Retinopath*) or all(neovascular glaucoma) or all(macular degeneration) or all(macular edema) or all(choroidal neovasculari?ation) or all(vitreous haemorrhag*) or all(vitreous hemorrhage*) or all(retinal vein occlusion)) = 426 results

### NIH Reporter

Date Searched: February 3, 2016

(aflibercept or EYLEA or bevacizumab or Avastin or ranibizumab or Lucentis) AND ;Search in: Projects AdminIC: All; Fiscal Year: Active Projects = 2 results

### AHRQ Gold

Date Searched: February 3, 2016

aflibercept or EYLEA or bevacizumab or Avastin or ranibizumab or Lucentis = 0 results