# SUMMARY AND DISCUSSION

The overarching finding from this systematic review is that the available evidence regarding perioperative antiplatelet management in patients with cerebrovascular or peripheral vascular disease undergoing non-cardiac, non-emergent surgery is insufficient to conclusively guide clinical practice. Study heterogeneity, specifically as it relates to the different aspects of APT – pre- and perioperative management, timing of cessation, restarting therapy, and type of APT – combined with small sample sizes, limits the ability to draw conclusions. Additionally, the varied range of invasiveness of the procedure likely contributes to the operative bleeding risk and thrombotic risk, yet many studies lack sufficient detail to assess the impact of procedure on outcomes. It is also likely that factors other than perioperative APT may be in part responsible for differences in bleeding and thrombotic outcomes.

## SUMMARY OF EVIDENCE BY KEY QUESTION

Thirteen observational studies provided some detail regarding the pre- and perioperative management of APT and its relationship to bleeding and thrombotic outcomes. Studies were generally small and indications were both inadequately described and deviated substantially from our target population. The perioperative management of APT agents was heterogeneous with significant contamination issues. Only 3 of the 13 studies showed an adverse association between APT agent and bleeding outcomes, primarily a function of intraoperative need for transfusion. There was no consistent difference in thrombotic, readmission, or mortality outcomes based on pre- and perioperative management of APT.

### Key Question 2

Only a small subset of studies evaluated the timing of APT discontinuation, with significant intra- and inter-study variation, limiting our ability to draw conclusions.

### Key Question 3

Few studies reported results stratified by type of surgical procedure, and among those that did, there was no clear difference in outcomes depending on perioperative antiplatelet strategy.

### Key Question 4

Studies were too small and did not include enough detail to associate outcomes with type of APT agent.

### Key Question 5

Evidence for the impact of timing for resuming APT was absent from the identified literature.

## LIMITATIONS

The primary limitation for this systematic review is the quantity and quality of the available evidence. Given the heterogeneity observed, the data suggest that variables other than the antiplatelet strategy play a role in determining perioperative bleeding or thrombotic outcome rates, and in most cases these other variables were not identified or not adequately able to be controlled for in these observational studies.

We theorize that several factors may work in conjunction and be associated with bleeding and thrombotic outcomes, but the data were too limited to help address this. For example, it is likely that the invasiveness of the procedure combined with the APT strategy may be associated with bleeding and thrombotic outcomes. However, studies often included multiple procedures with variable bleeding risk profiles. Further, APT management varied both within and between studies without stratified results. This prevented us from identifying whether one APT management, for a particular type of procedure or group of procedures, was protective or harmful. Indication for APT agent is likely a very important factor that was either absent from studies or was not used to stratify results. Patients with mild PVD are likely at much different thrombotic risk than a patient who required a complex endovascular intervention. Medical optimization was absent from the studies. Additionally, other perioperative management can also impact development of thrombotic events, such as perioperative anticoagulation and mobilization, which was not reported in the studies.

### Publication Bias

Publication bias is always a concern in any systematic review. We had too few studies to conduct statistical tests for the possible presence of publication bias, so we cannot provide a data-based estimate of its likelihood.

### Study Quality

Overall, the quality of the evidence was insufficient to support strong conclusions across the key questions.

### Heterogeneity

Heterogeneity is a major limitation of this systematic review, as the variation in reported bleeding and thrombotic outcomes between studies was large and did not suggest a pattern between perioperative antiplatelet management and outcomes.

### Applicability of Findings to the VA Population

Only 2 studies were conducted in a VA setting, both from the same system reporting on the same procedure (endoscopy with polypectomy). Even though the remaining studies were not in VA populations, we judged these results as being moderately or even strongly applicable to VA since the enrolled patients were very likely to moderately or strongly resemble VA patients, except with respect to gender.

## RESEARCH GAPS/FUTURE RESEARCH

There is obviously a very large research gap, as we were unable to find evidence sufficient to reach conclusions for any of the Key Questions. The evidence does suggest that differences in outcomes due to perioperative antiplatelet management are likely to be smaller than differences in outcomes due to other clinical factors. This suggests that observational studies are going to have difficulty identifying or balancing these other clinical factors, thus limiting their value in reaching strong conclusions about perioperative antiplatelet management strategies. Randomized studies would potentially balance these other clinical factors. Yet randomized studies present their own problem – namely sample size. Trying to detect small effects requires large samples. For example, if baseline rates of thrombotic outcomes are 5%, to detect a rate reduction of 2% with 80% power would require a sample size of almost 1500 patients per arm. Similarly, if the rate of bleeding is 5% at baseline, then it would require more than 400 patients in each arm to have 80% power to detect a doubling of this to 10%. These study samples are much larger than any of the observational studies included in this review. Further, if any additional stratifying variables are included, such as indication of APT, invasiveness of surgery, or timing of APT stopping/resumption, this would greatly add to the needed sample size. Alternatively, if a randomized trial seems unlikely, a thoughtful and well-designed retrospective review may be helpful. A VA study conducted by Hawn et al evaluated perioperative MACE in patients undergoing non-coronary surgery after coronary stent placement.^19^ This study found that, regardless of stent type, the optimal window for operating appears to be 6 months after implantation, a finding that was later incorporated into the American College of Cardiology (ACC) / American Heart Association (AHA) guidelines.^20^ A study of similar design in patients with peripheral stents and/or cerebrovascular stents would be informative.

## CONCLUSIONS

Published studies of the association between perioperative APT management and outcomes in patients with cerebrovascular or peripheral vascular disease undergoing non-cardiac, non-emergent surgery have challenging methodologic limitations and heterogeneous results, and do not provide sufficient evidence to moderately or strongly support any clinical recommendation. The results suggest that clinical factors other than perioperative APT management may be more responsible for bleeding and thrombotic outcomes. It is likely that a clinical trial of large size would be needed to more definitely provide evidence about this clinical decision.