# RESULTS

## LITERATURE FLOW

Our literature searches, expert recommendations, and reference mining identified 613 potentially relevant citations, of which 56 were included at the abstract screening. All 56 abstracts were included and obtained as full-text publications. Forty-three studies were excluded for the following reasons: non-systematic review (n=14), less than 70% of patients on DAPT (n=11), not measuring outcome of interest (n=5), did not present original data (n=3), not population of interest (n=2), exclusively coronary stents (n=2), letter or commentary (n=4), study protocol (n=1), or case report (n=1). A total of 13 publications were identified at full-text review as includes that contributed to our final sample. See Figure 1 for literature flow. Details of included studies are provided in Appendix C. A full list of these excluded studies from the full-text review is included in Appendix D.

Figure 1 Literature Flow Chart

## KEY QUESTION 1 Among patients on APT for cerebrovascular or peripheral vascular disease undergoing elective non-cardiac surgical procedures, including intraocular procedures, what are the benefits and harms of holding APT prior to surgery?

We identified 13 studies from full-text review. None were clinical trials. Twelve were cohort studies, of which 3 were prospective and 9 were retrospective. One additional study utilized a case-control design. Of the 13 studies, samples were generally small, with only one study reporting on over 1000 patients. Three studies included fewer than 100 patients, 5 reported 100-200 patients, and 4 reported 201-1000 patients. Eleven studies were conducted in an academic setting and 2 were conducted in a Veterans Affairs (VA) setting. Only 4 studies reported results from more than one site. Eight studies were conducted in the United States, with the remaining 5 studies coming from India, Ireland, the United Kingdom, and Canada.

The quality of studies was variable: most included all or a representative sample of eligible patients and used medical records to assess outcomes, and most were retrospective and single site. Methods for adjusting differences in other clinical variables were heterogeneous (Table 1).

Table 1 Quality Assessment for Included Studies

| Study Design | Generalizability | Sample Representativeness | Assessment of Outcomes
Anderson, 2014 | - | - | + | +
Chernoguz, 2011 | - | - | + | +
Feagins, 2011 | - | - | + | +
Feagins, 2013 | + | + | + | +
Girotra, 2014 | + | - | ? | +
Hussain, 2007 | - | + | + | +
Jacob, 2014 | - | - | + | +
Mackinnon, 2008 | - | + | + | +
McCunniff, 2016 | - | - | + | +
Radovanovic, 2012 | - | - | ? | +
Ryan, 2013 | + | + | + | +
Strosberg, 2016 | - | - | + | +
Toepfer, 2013 | - | - | + | +

Study Design: (+) Prospective, (-) Retrospective

Generalizability: (+) Multi site, (-) Single Site

Sample representativeness: (+) Consecutive or all patients (?) Unclear

Assessment of Outcomes: (+) Medical Chart Review

Appendix C shows the evidence table for the 13 studies. An ideal study would provide the following data to assess the relationship between APT and postoperative outcomes: indication for APT (eg, peripheral vascular disease [PVD] with or without stent), the preoperative APT regimen (ie, the medications they were taking at baseline, before surgery was considered), and details about the perioperative management such as which agents were continued and which were held, and if held, for how many days preoperatively. Postoperative outcomes should be stratified based on these variables. As a hypothetical example, we would like to see postoperative bleeding rates only for those patients with a carotid stent, on preoperative DAPT, where the clopidogrel was held for 5 days preoperatively and the aspirin was continued. We did not identify any study that fulfilled all of these criteria.

Five of the included studies did not provide any information about indication for APT, preventing stratification along this important covariate. Adverse thrombotic events are therefore difficult to interpret for these studies. Of the 8 studies that did include some information about indication, the dominant indication for APT was a manifestation of coronary artery disease such as angina, post-myocardial infarction, post-coronary artery bypass, or post-percutaneous coronary intervention. Cerebrovascular and peripheral vascular indications were rare; for example, in the largest study, only 26 of 546 patients were on APT for history of an ischemic stroke (IS).^6^ Only one study^7^ had a significant proportion of individuals on APT for an indication of interest– this single-site retrospective review of 200 patients included 58 patients with a history of peripheral stent and 34 patients with a history of IS compared to 75 patients with an indication for coronary stent. However, outcome rates were not stratified by these indications, meaning only aggregate data are presented and we cannot attribute adverse outcomes to patients with peripheral stents, IS, etcetera. Further, most studies provided inadequate details about indication; for example, PVD would be listed as the indication but there would be no details about severity (ie, claudication versus critical limb ischemia), prior interventions (ie, whether or not surgery or endovascular intervention had been conducted), or any details about the interventions such as the complexity, presence or absence of stent, location of stent, etcetera. All 13 studies provided some details about pre- and perioperative APT management. The 12 cohort studies typically adopted 1 of 2 study designs based on their labeling of individuals to intervention or control arms. The first design^6,8-13^ labeled patients based on their preoperative APT (eg, clopidogrel, DAPT, etc) while the second design^7,14-17^ labeled patients based on their perioperative management (eg, all patients in the study were on preoperative clopidogrel but interventions and controls were labeled based on whether the agent was successfully held perioperatively). For the cohort studies adopting the first design, the sample size of patients on P2Y_12_ inhibitor or DAPT was generally very small. For example, one study of 454 patients only included 13 patients on clopidogrel while 369 patients served as “controls.”^8^ 3 cohort studies included agents that were not of interest for this report including coumadin and dipyridamole.^10,13,17^ Further, study arms often suffered from significant contamination of APT agents. For example, studies often tried to compare those patients on a P2Y_12_ inhibitor to those not on the P2Y_12_ inhibitor; however, aspirin use was common, but disparate, between the 2 arms. Some studies did not comment on use of aspirin or other relevant APT/anticoagulant at all.

Of the 12 cohort studies, 9 did not find a difference in major bleeding outcome rates. Of the 3 studies that did show a difference, 2 evaluated small cohorts of patients on preoperative clopidogrel and compared those that did and did not receive a dose within 7 days of the procedure.^14,15^ Both showed higher rates of intraoperative transfusions, and possibly increased bleeding postoperatively, although definitions were vague on this latter point. The third study compared patients on preoperative clopidogrel that was continued to those patients not on preoperative clopidogrel and found slightly higher rates of clinically significant delayed bleeding following endoscopic polypectomy (2.4% versus 0%).^11^ 87% of patients in the clopidogrel group were also on aspirin while 40% of controls were also on aspirin, a potentially major confounder to consider when interpreting the results.

Seven of the cohort studies reported some type of thrombotic outcome in addition to major bleeding. All 7 found no statistical difference or reported no events in the 2 arms. Four studies reported on readmission and/or mortality rates with 3 finding no difference. One small retrospective cohort compared patients who received and did not received clopidogrel within 7 days of a general surgical procedure and found a higher 30-day mortality rate amongst those that received clopidogrel.^15^ However, this study found no difference in thrombotic outcomes, and the etiology of the mortality was not elucidated.

The results of the one case-control study are reported here.^18^ In this 2007 two-site Canadian study, confirmed cases of post-ERCP bleeding were compared to those without bleeding to assess risk factors. The researchers created a variable for APT exposure within 10 days of the procedure and included aspirin and P2Y_12_ inhibitors as well as COX2 inhibitors and NSAIDs. Exposure to APT was not significantly associated with post-ERCP major bleeding. No thrombotic or other outcomes were reported.

### Summary of Findings

Thirteen observational studies provided some detail regarding the pre- and perioperative management of APT and its relationship to bleeding and thrombotic outcomes. Studies were generally small and indications were both inadequately described and deviated substantially from our target population. The perioperative management of APT agents was heterogeneous with significant contamination issues. Only 3 of the 13 studies showed an adverse association between APT agent and bleeding outcomes, primarily a function of intraoperative need for transfusion. There was no consistent difference in thrombotic, readmission, or mortality outcomes based on pre- and perioperative management of APT.

### Quality of Evidence for Key Question 1

We judged the quality of evidence as insufficient to make conclusions.

## KEY QUESTION 2 How does benefit/risk vary by the timing of discontinuation?

The timing of discontinuation of APT cessation varied between studies and among individual patients within studies. Four studies compared patients based on timing of discontinuation of APT agents^7,14-16^; however, 2 studies used 7 days as a cutoff, 1 used 5 days as a cutoff, and 1 used 2 days as the cutoff. Two of these 4 studies included mostly patients with DAPT, one included patients on clopidogrel (with unknown ASA status), and one included patients predominantly on ASA alone. An additional layer of confounding is that some studies combined patients not on APT preoperatively with those on APT preoperatively but held therapy into a singular control group.

No included study systematically assessed the impact of timing of APT cessation on any clinical outcomes.

### Summary of Findings

Only a small subset of studies evaluated the timing of APT discontinuation, with significant intra- and inter-study variation, limiting our ability to draw conclusions.

### Quality of Evidence for Key Question 2

We judged the quality of evidence as insufficient regarding the timing of discontinuation of APT prior to surgery.

## KEY QUESTION 3 How does benefit/risk vary by type of surgical procedure, including intraocular procedures?

Studies were grouped into 4 categories based on the type of procedure – 4 studies addressed specific surgical procedures, such as laparoscopic cholecystectomy or total knee arthroplasty^9,10,14,17^; 2 studies were non-specific and included either major abdominal surgeries^15^ or a mix of major abdominal, vascular, and thoracic procedures^7^; 5 studies only addressed minor procedures such as minor oral surgery or endoscopy^6,11,12,16-18^; one study addressed ophthalmology.^13^ Despite categorization, there was significant variation within each category; for example, concern of bleeding in lumbar spine surgery is not equivalent to the risk in laparoscopic cholecystectomy or total knee arthroplasty. Only 2 studies explicitly evaluated “major abdominal surgery,” with one finding no difference in bleeding rates, and one finding increased risk of transfusion, primarily driven by intraoperative transfusions. Neither found a difference in thrombotic events. Of the 5 studies that addressed minor procedures, only one found an increased risk of clinically significant delayed bleeding for patients who continued P2Y_12_ therapy through endoscopic procedures.

Only one study of antiplatelet management and ocular procedures was identified.^13^ This study prospectively studied 85 patients taking antiplatelet or anticoagulant therapy undergoing 107 vitreoretinal procedures. Patients were taking APT for a diversity of reasons with only 11 patients with the indication as cerebrovascular disease and 4 for peripheral vascular disease. Of the 107 cases, 72% were on ASA alone, 8% on clopidogrel alone, and 10% each on DAPT or coumadin. All patients continued therapy through the perioperative period. The primary outcome was intraoperative and postoperative bleeds, with no thrombotic or other clinical outcomes reported. On multivariate analysis there was no association between APT or anticoagulant type and intraoperative or postoperative bleeding. Further, there were no cases of catastrophic suprachoroidal hemorrhage leading to loss of vision across the entire study.

### Summary of Findings

Few studies reported results stratified by type of surgical procedure, and among those that did, there was no clear difference in outcomes depending on perioperative antiplatelet strategy.

### Quality of Evidence for Key Question 3

We judged the evidence as insufficient regarding the relationship between perioperative antiplatelet strategy and outcomes depending on the type of surgical procedure.

## KEY QUESTION 4 How does benefit/risk vary by type of APT?

In general, studies were either too small or did not include enough detail to compare APT agents to one another. The one study that enrolled over 1000 patients identified 310 patients on aspirin alone, 97 patients on clopidogrel alone, 139 patients on DAPT and 575 patients on neither (“controls”).^6^ All patients were undergoing minor oral surgical procedures and were continued on their preoperative regimen. They found no difference in transfusions postoperatively across the 4 cohorts. They did not evaluate thrombotic outcomes. Several studies included patients on multiple APT strategies, but did not stratify results based on these strategies. For example, one study evaluated 200 patients on clopidogrel preoperatively of which 143 were on DAPT.^7^ Unfortunately, the results are not stratified by those on DAPT and those on clopidogrel.

### Summary of Findings

Studies were too small and did not include enough detail to associate outcomes with type of APT agent.

### Quality of Evidence for Key Question 4

We judged the evidence as insufficient regarding the association between the type of APT and outcomes.

## KEY QUESTION 5 How does benefit/risk vary by the timing of resuming APT?

No study reported the timing of resumption of APT.

No included study systematically assessed the impact of timing of resuming APT on any clinical outcomes.

### Summary of Findings

Evidence for the impact of timing of resuming APT was absent from the identified literature.

### Quality of Evidence for Key Question 5

We judged the evidence as insufficient regarding the timing of resumption of APT.