# REFERENCES

1 Fleisher LA, Fleischmann KE, Auerbach AD, . 2014 ACC/AHA guideline on perioperative cardiovascular evaluation and management of patients undergoing noncardiac surgery: executive summary: a report of the American College of Cardiology/American Heart Association Task Force on practice guidelines. Developed in collaboration with the American College of Surgeons, American Society of Anesthesiologists, American Society of Echocardiography, American Society of Nuclear Cardiology, Heart Rhythm Society, Society for Cardiovascular Angiography and Interventions, Society of Cardiovascular Anesthesiologists, and Society of Vascular Medicine Endorsed by the Society of Hospital Medicine. J Nucl Cardiol. 2015;22(1):162-215.25523415
2 Maggard Gibbons M U J, Macqueen I,; Miake-Lye IM,; Shanman R,; Beroes JM, Shekelle PG. Management of antiplatelet therapy among patients on antiplatelet therapy for coronary or cerebrovascular disease or with prior percutaneous cardiac interventions undergoing elective surgery: A systematic review. Washington DC: Department of Veterans Affairs;2016.
3 Writing Committee M, Gerhard-Herman MD, Gornik HL, . 2016 AHA/ACC Guideline on the Management of Patients with Lower Extremity Peripheral Artery Disease: Executive Summary. Vasc Med. 2017;22(3):NP1-NP43.28494710
4 Higgins JP, Altman DG, Gøtzsche PC, . The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ (Clinical research ed). 2011;343:d5928.
5 GRADE working group. 2014; http://www.gradeworkinggroup.org/. Accessed 09/25/15.
6 Girotra C, Padhye M, Mandlik G, . Assessment of the risk of haemorrhage and its control following minor oral surgical procedures in patients on anti-platelet therapy: a prospective study. International journal of oral and maxillofacial surgery. 2014;43(1):99-106.24074486
7 Strosberg DS, Corbey T, Henry JC, Starr JE. Preoperative antiplatelet use does not increase incidence of bleeding after major operations. Surgery. 2016;160(4):968-976.27450711
8 McCunniff PT, Young ES, Ahmadinia K, Kusin DJ, Ahn UM, Ahn NU. Chronic Antiplatelet Use Associated With Increased Blood Loss in Lumbar Spinal Surgery Despite Adherence to Protocols. Orthopedics. 2016;39(4):e695-700.27111080
9 Anderson K, Jupiter DC, Abernathy SW, Frazee RC. Should clopidogrel be discontinued before laparoscopic cholecystectomy? American journal of surgery. 2014;208(6):926-931; discussion 930-921.25435299
10 Radovanovic I, Queally J, Bahari S, Sproule J, McElwain J. Anticoagulant use and its effect on bleeding and complications in total knee arthroplasty. Acta orthopaedica Belgica. 2012;78(2):187-191.22696988
11 Feagins LA, Iqbal R, Harford WV, . Low rate of postpolypectomy bleeding among patients who continue thienopyridine therapy during colonoscopy. Clinical gastroenterology and hepatology : the official clinical practice journal of the American Gastroenterological Association. 2013;11(10):1325-1332.23403011
12 Feagins LA, Uddin FS, Davila RE, Harford WV, Spechler SJ. The rate of post-polypectomy bleeding for patients on uninterrupted clopidogrel therapy during elective colonoscopy is acceptably low. Digestive diseases and sciences. 2011;56(9):2631-2638.21455672
13 Ryan A, Saad T, Kirwan C, Keegan DJ, Acheson RW. Maintenance of perioperative antiplatelet and anticoagulant therapy for vitreoretinal surgery. Clinical & experimental ophthalmology. 2013;41(4):387-395.23094982
14 Jacob AK, Hurley SP, Loughran SM, Wetsch TM, Trousdale RT. Continuing clopidogrel during elective total hip and knee arthroplasty: assessment of bleeding risk and adverse outcomes. The Journal of arthroplasty. 2014;29(2):325-328.23856063
15 Chernoguz A, Telem DA, Chu E, Ozao-Choy J, Tammaro Y, Divino CM. Cessation of clopidogrel before major abdominal procedures. Archives of surgery (Chicago, Ill : 1960). 2011;146(3):334-339.
16 Toepfer NJ, Baylor K, Henry Y, Simmons J, Berger PB. The effect of antiplatelet and anticoagulant therapy on the clinical outcome of patients undergoing ureteroscopy. Urology. 2013;82(4):773-779.23876586
17 Mackinnon B, Fraser E, Simpson K, Fox JG, Geddes C. Is it necessary to stop antiplatelet agents before a native renal biopsy? Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. 2008;23(11):3566-3570.
18 Hussain N, Alsulaiman R, Burtin P, . The safety of endoscopic sphincterotomy in patients receiving antiplatelet agents: a case-control study. Alimentary pharmacology & therapeutics. 2007;25(5):579-584.17305758
19 Hawn MT, Graham LA, Richman JS, Itani KM, Henderson WG, Maddox TM. Risk of major adverse cardiac events following noncardiac surgery in patients with coronary stents. Jama. 2013;310(14):1462-1472.24101118
20 Levine GN, Bates ER, Bittl JA, . 2016 ACC/AHA guideline focused update on duration of dual antiplatelet therapy in patients with coronary artery disease: A report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. The Journal of thoracic and cardiovascular surgery. 2016;152(5):1243-1275.27751237