# METHODS

## TOPIC DEVELOPMENT

This topic was developed in response to a nomination by Dr. Arthur Wallace, Chief of Anesthesia at the San Francisco VAMC, and Dr. John Sum-Ping, Director of National Anesthesia Service. Key questions were then developed with input from the topic nominator, the ESP coordinating center, the review team, and the technical expert panel (TEP).

The Key Questions were:

1. Among patients on APT for cerebrovascular disease or peripheral vascular disease undergoing elective non-cardiac surgical procedures, including intraocular procedures, what are the benefits and harms of holding APT prior to surgery?
2. How does benefit/risk vary by the timing of discontinuation?
3. How does benefit/risk vary by type of surgical procedure, including intraocular procedures?
4. How does benefit/risk vary by type of APT?
5. How does benefit/risk vary by the timing of resuming APT?

The review was submitted to PROSPERO: CRD42017062522.

## SEARCH STRATEGY

We conducted searches in PubMed from inception to 10/18/2016 (see Appendix A for full search strategy). The search in PubMed used a broad set of terms relating to APT and non-cardiac surgery.

## STUDY SELECTION

Four team members, working in pairs, independently screened the titles of retrieved citations. Citations deemed relevant by at least one reviewer were then screened at the full-text level by 2 independent reviewers. Any disagreements were resolved by consensus decision after study team discussion. To be included, full texts needed to include: (1) The patients underwent elective, non-cardiac surgery, including endoscopy and minor procedures; (2) Patients were on dual antiplatelet therapy (DAPT) or single P2Y_12_ inhibitor therapy in the great majority of cases (>70%); (3) The majority of patients were on APT for peripheral vascular or cerebrovascular stents; (4) Details regarding pre- and perioperative management of APT were described, with outcomes stratified by strategy; (5) The article presented original data (eg,, not a review, commentary, or duplicate publication using the same data as another included publication); (6) The article reported adverse events and/or bleeding outcomes; and (7) Published in the English language. We did not exclude studies based on the type of APT (ie,, all P2Y_12_ agents were eligible).

Our initial full-text review was limited to studies where all or the great majority of patients had peripheral or cerebrovascular stents, in line with the previous ESP report that focused on coronary stents.^2^ Unfortunately, no studies were identified using these criteria. We then broadened the screen, allowing inclusion of studies where the majority of patients had indications for peripheral vascular or cerebrovascular disease, with or without stents. Again, no studies were identified. Finally, we allowed the search to include any study that did not focus exclusively on patients with coronary stents, which identified the 13 studies reported here.

The following PICOTS framework describes our inclusion criteria:

Participants/population: Patients undergoing elective non-cardiac surgery on preoperative DAPT or P2Y_12_ inhibitor therapy for indications other than coronary stents.

Intervention(s): Stopping all or some APT, bridging therapy.

Comparators: Not stopping or stopping at different times relative to the surgical procedure, as well as by drug.

Outcomes: Bleeding outcomes, thrombotic outcomes, and other clinical outcomes.

Timing: There was no restriction on timing.

Setting: All patients were undergoing surgery, either in inpatient or outpatient/ambulatory arenas.

## DATA ABSTRACTION

Data extraction was completed in duplicate. All discrepancies were resolved with full-group discussion. We abstracted data on the following: study design, setting, number of sites, country of origin, sample size, surgical procedures, indications for APT, APT management including preoperative, perioperative, and postoperative (when available), and outcomes including major bleeding, thrombotic outcomes, and other clinical outcomes. Bleeding outcomes were reported variably, including estimates of blood loss, postoperative hemoglobin changes, need for transfusion intraoperatively or postoperatively, and need for repeat procedure or operation for bleeding. After consultation with 2 practicing surgeons, we included only clinically relevant bleeding outcomes such as need for transfusion, re-operation, or escalation of care. Minor bleeding, such as a wound hematoma, changes in estimated blood loss without the need for transfusion, or the application of topical antithrombotic agents were not included. We included the following thrombotic outcomes: deep vein thrombosis (DVT); pulmonary embolus (PE); major adverse cardiac event (MACE) including myocardial infarction (MI), sudden cardiac death, or stent thrombosis; ischemic strokes (IS) or transient ischemic attacks (TIA); and peripheral stent thrombosis. Additional outcomes deemed clinically relevant to the assessment of risks and benefits of APT, such as need for reoperation, readmission and mortality, were included under “other clinical outcomes.” Surgery-specific complications, such as surgical site infections, anastomotic leaks, as well as length of stay and utilization metrics, were not extracted.

## QUALITY ASSESSMENT

We had planned on assessing any randomized controlled trials with the Cochrane Risk of Bias tool.^4^ However, we identified no trials. Cohort studies were assessed on design (eg,, retrospective versus prospective), number of sites, representativeness of the enrolled subjects, and assessments of the exposure and outcome(s).

## DATA SYNTHESIS

Data were too heterogeneous to support statistical pooling, and due to heterogeneity both in the outcomes reported and the APT strategies, we were unable to graphically plot the data either. Data were synthesized in a narrative format only.

## RATING THE BODY OF EVIDENCE

Where possible a summary of findings and quality of evidence table was used to summarize the existing evidence. Based on the GRADE working group,^5^ the quality of the evidence was categorized as follows:

High: We are very confident that the true effect lies close to that of the estimate of the effect.

Moderate: We are moderately confident in the effect estimate. The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.

Low: Our confidence in the effect estimate is limited. The true effect may be substantially different from the estimate of the effect.

Very low/Insufficient: We have very little confidence in the effect estimate. The true effect is likely to be substantially different from the estimate of effect.

GRADE evaluates the quality of the evidence across all identified studies contributing to the outcome of interest.

## PEER REVIEW

A draft version of the report will be reviewed by technical experts and clinical leadership. Reviewer comments and our response are documented in Appendix B.