# INTRODUCTION

The perioperative management of antiplatelet therapy (APT) for patients with coronary, cerebrovascular, or peripheral vascular stents remains unclear. After percutaneous coronary intervention, American College of Cardiology (ACC) and American Heart Association (AHA) guidelines recommend delaying elective non-cardiac surgery, ideally 6 months following drug-eluting stent placement and 30 days after bare metal stent placement.^1^ For patients on dual antiplatelet therapy (DAPT), ACC/AHA guidelines recommend continuing at least aspirin (ASA) throughout the perioperative period and restarting the P2Y_12_ inhibitor as soon as possible following surgery. However, this latter recommendation is based on expert opinion and was the focus of a recent ESP report.^2^ The conclusion of this report was that studies evaluating APT therapy in patients with coronary stents had significant methodologic limitations and that APT therapy likely has a small impact on perioperative bleeding and major adverse cardiac event (MACE) outcomes, compared to other clinical factors such as operative urgency and timing since stent implantation.

There are a number of indications for APT therapy beyond coronary stents, most notably peripheral vascular and cerebrovascular disease. All patients with symptomatic peripheral artery disease are recommended to be on APT, typically monotherapy with either aspirin or clopidogrel.^3^ However, DAPT (typically with ASA and clopidogrel) is common, especially amongst the highest-risk patients – those following endovascular procedures for critical limb ischemia.^3^ Duration of APT for vascular disease is typically lifelong, unless the patient develops a significant complication, such as a bleeding event. The perioperative management of APT in the setting of elective non-cardiac surgery, specifically the decision about whether to stop APT before surgery and for how long, requires balancing overall thrombotic risk against the risk of bleeding with surgery.

To help clinicians, patients, and policymakers with this important decision, we conducted a systematic review of the published literature to address the following questions. What are the risks and benefits of APT in the perioperative period for patients on APT for cerebrovascular or peripheral vascular disease? Do the risks and benefits vary by timing of discontinuation and resumption of APT? And do the risks and benefits vary by the type of procedure or the type of APT agent?