# APPENDIX D CITATIONS FOR EXCLUDED STUDIES

## Less than 70% on DAPT (n=11)

1 Rahman M, Donnangelo LL, Neal D, Mogali K, Decker M, Ahmed MM. Effects of Perioperative Acetyl Salicylic Acid on Clinical Outcomes in Patients Undergoing Craniotomy for Brain Tumor. World neurosurgery. 2015;84(1):41-47.25727304
2 Alcock RF, Naoum C, Aliprandi-Costa B, Hillis GS, Brieger DB. The peri-operative management of anti-platelet therapy in elective, non-cardiac surgery. International journal of cardiology. 2013;167(2):374-377.22273438
3 Antolovic D, Rakow A, Contin P, . A randomised controlled pilot trial to evaluate and optimize the use of anti-platelet agents in the perioperative management in patients undergoing general and abdominal surgery--the APAP trial (ISRCTN45810007). Langenbeck’s archives of surgery. 2012;397(2):297-306.
4 De Martino RR, Beck AW, Hoel AW, . Preoperative antiplatelet and statin treatment was not associated with reduced myocardial infarction after high-risk vascular operations in the Vascular Quality Initiative. Journal of vascular surgery. 2016;63(1):182-189.e182.26409843
5 De Martino RR, Eldrup-Jorgensen J, Nolan BW, . Perioperative management with antiplatelet and statin medication is associated with reduced mortality following vascular surgery. Journal of vascular surgery. 2014;59(6):1615-1621, 1621.e1611.24439325
6 De Martino RR, Beck AW, Hoel AW, . Participation in the Vascular Quality Initiative is associated with improved perioperative medication use, which is associated with longer patient survival. Journal of vascular surgery. 2015;61(4):1010-1019.25601506
7 Dzupa V, Waldauf P, Motovska Z, . Risk comparison of bleeding and ischemic perioperative complications after acute and elective orthopedic surgery in patients with cardiovascular disease. Arch Orthop Trauma Surg. 2016;136(7):907-911.27146820
8 Hermiz S, Larsen P, Galletly DC, Harding SA. Peri-operative management of anti-platelet agents. ANZ J Surg. 2009;79(7-8):521-525.19694659
9 Joo MS, Ahn BM, Kim HJ, . Evaluation of feasible timing of elective noncardiac procedure after antiplatelet discontinuation in patients treated with antiplatelet agents. Journal of investigative medicine : the official publication of the American Federation for Clinical Research. 2014;62(5):808-812.24569484
10 Ong WL, Koh TL, Fletcher J, Gruen R, Royce P. Perioperative Management of Antiplatelets and Anticoagulants Among Patients Undergoing Elective Transurethral Resection of the Prostate--A Single Institution Experience. Journal of endourology. 2015;29(11):1321-1327.26154769
11 Wolf AM, Pucci MJ, Gabale SD, . Safety of perioperative aspirin therapy in pancreatic operations. Surgery. 2014;155(1):39-46.23890963

## Non Systematic Review (n=14)

1 Abdel Samie A, Theilmann L. Endoscopic procedures in patients under clopidogrel/dual antiplatelet therapy: to do or not to do? Journal of gastrointestinal and liver diseases : JGLD. 2013;22(1):33-36.23539388
2 Chassot PG, Delabays A, Spahn DR. Perioperative use of anti-platelet drugs. Best practice & research Clinical anaesthesiology. 2007;21(2):241-256.17650775
3 Chassot PG, Marcucci C, Delabays A, Spahn DR. Perioperative antiplatelet therapy. American family physician. 2010;82(12):1484-1489.21166368
4 Degirmenci SE, Steib A. Peri-operative management of anticoagulation and antiplatelet therapy in gastrointestinal surgery. Journal of visceral surgery. 2014;151(2):125-135.24631468
5 Di Minno MN, Prisco D, Ruocco AL, Mastronardi P, Massa S, Di Minno G. Perioperative handling of patients on antiplatelet therapy with need for surgery. Internal and emergency medicine. 2009;4(4):279-288.19533288
6 Gandhi S, Narula N, Mosleh W, Marshall JK, Farkouh M. Meta-analysis: colonoscopic post-polypectomy bleeding in patients on continued clopidogrel therapy. Alimentary pharmacology & therapeutics. 2013;37(10):947-952.23530880
7 Gerstein NS, Schulman PM, Gerstein WH, Petersen TR, Tawil I. Should more patients continue aspirin therapy perioperatively?: clinical impact of aspirin withdrawal syndrome. Annals of surgery. 2012;255(5):811-819.22470078
8 Kiire, C. A., Mukherjee, R., Ruparelia, N., Keeling, D., Prendergast, B., & Norris, J. H. Managing antiplatelet and anticoagulant drugs in patients undergoing elective ophthalmic surgery. British Journal of Ophthalmology, bjophthalmol-2014.
9 McKenzie JL, Douglas G, Bazargan A. Perioperative management of anticoagulation in elective surgery. ANZ J Surg. 2013.
10 McKenzie JL, Douglas G, Bazargan A. Perioperative management of anticoagulation in elective surgery. ANZ J Surg. 2013;83(11):814-820.23601136
11 Mohr TS, Brouse SD. Perioperative management of antiplatelet agents. Orthopedics. 2012;35(8):687-691.22868592
12 O’Riordan JM, Margey RJ, Blake G, O’Connell PR. Antiplatelet agents in the perioperative period. Archives of surgery (Chicago, Ill : 1960). 2009;144(1):69-76; discussion 76.
13 Sahebally SM, Healy D, Coffey JC, Walsh SR. Should patients taking aspirin for secondary prevention continue or discontinue the medication prior to elective, abdominal surgery? Best evidence topic (BET). International journal of surgery (London, England). 2014;12(5):16-21.
14 Steele MJ, Fox JS, Fletcher JP, Grigg LE, Bell G. Clopidogrel dilemma for orthopaedic surgeons. ANZ J Surg. 2011;81(11):774-784.22295376

## Not measuring outcome of interest (n=5)

1 Kim SH, Lee JH, Joo W, . Analysis of the risk factors for development of post-operative extradural hematoma after intracranial surgery. British journal of neurosurgery. 2015;29(2):243-248.25301742
2 Mantas GK, Antonopoulos CN, Sfyroeras GS, . Factors Predisposing to Endograft Limb Occlusion after Endovascular Aortic Repair. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2015;49(1):39-44.
3 Okano A, Oya S, Fujisawa N, . Analysis of risk factors for chronic subdural haematoma recurrence after burr hole surgery: optimal management of patients on antiplatelet therapy. British journal of neurosurgery. 2014;28(2):204-208.23952136
4 Trellopoulos G, Georgiadis GS, Nikolopoulos ES, Kapoulas KC, Georgakarakos EI, Lazarides MK. Antiplatelet treatment and prothrombotic diathesis following endovascular abdominal aortic aneurysm repair. Angiology. 2014;65(9):783-787.24101707
5 Wild JB, Dattani N, Stather P, Bown MJ, Sayers RD, Choke E. Effect of anticoagulation and antiplatelet therapy on incidence of endoleaks and sac size expansions after endovascular aneurysm repair. Ann Vasc Surg. 2014;28(3):554-559.24090829

## Coronary stents (n=2)

1 Abdel Samie A, Stumpf M, Sun R, Theilmann L. Biliary-Pancreatic Endoscopic and Surgical Procedures in Patients under Dual Antiplatelet Therapy: A Single-Center Study. Clinical endoscopy. 2013;46(4):395-398.23964338
2 Abdel Samie AA, Sun R, Vohringer U, Theilmann L. Safety of endoscopic sphincterotomy in patients under dual antiplatelet therapy. Hepato-gastroenterology. 2013;60(124):659-661.23187292

## Letter/commentary (n=4)

1 Belletrutti PJ, Heitman SJ. Management of anticoagulants and antiplatelet agents in elective endoscopy: weighing the risks and benefits. Canadian journal of gastroenterology = Journal canadien de gastroenterologie 2007;21(9):553-555.17853948
2 Al Busafi SA. Management of antiplatelets in elective GI endoscopies: a collaboration between the endoscopist and the cardiologist. Gastrointestinal endoscopy. 2009;69(1):185; author reply 185-186.19111701
3 Clevenger B, Jaggar S. Anti-platelet therapy in non-cardiac elective surgery. British journal of anaesthesia. 2012;108(4):699; author reply 699.
4 Mukherjee R, Kiire CA, Ruparelia N, Keeling D, Prendergast B, Norris JH. Managing antiplatelet and anticoagulant drugs in patients undergoing elective ophthalmic surgery. Authors’ response. The British journal of ophthalmology. 2014;98(8):1136-1137.24876457

## No original data (n=3)

1 Mitka M. Myocardial infarction risks remain for patients undergoing noncardiac elective surgery. Jama. 2014;311(19):1955-1956.24846020
2 Mukerji G, Munasinghe I, Raza A. A survey of the peri-operative management of urological patients on clopidogrel. Annals of the Royal College of Surgeons of England. 2009;91(4):313-320.19344548
3 Savage JR, Parmar A, Robinson PJ. Antiplatelet drugs in elective ENT surgery. The Journal of laryngology and otology. 2012;126(9):886-892.22892218

## Not population of interest (n=2)

1 Arias EJ, Patel B, Cross DT, 3rd, . Timing and nature of in-house postoperative events following uncomplicated elective endovascular aneurysm treatment. Journal of neurosurgery. 2014;121(5):1063-1070.25170666
2 Kim B, Kim K, Jeon P, . Thromboembolic complications in patients with clopidogrel resistance after coil embolization for unruptured intracranial aneurysms. AJNR American journal of neuroradiology. 2014;35(9):1786-1792.24831597

## Study protocol (n=1)

1 Antolovic D, Reissfelder C, Rakow A, . A randomised controlled trial to evaluate and optimize the use of antiplatelet agents in the perioperative management in patients undergoing general and abdominal surgery--the APAP trial (ISRCTN45810007). BMC surgery. 2011;11:7.

## Case report (n=1)

1 Harris K, Kebbe J. Endobronchial biopsies on aspirin and prasugrel. Heart, lung & circulation. 2015;24(6):e68-70.