# APPENDIX C EVIDENCE TABLES

Author, Year | Study Design | Setting, # of Sites | Country | Sample Size | Surgical Field | Indications for APT | Perioperative Management | | | | Major Bleeding | Thrombotic Outcomes | Other Outcomes
Author, Year | Study Design | Setting, # of Sites | Country | Sample Size | Surgical Field | Indications for APT | Preop | Periop | >5d? | Postop | Major Bleeding | Thrombotic Outcomes | Other Outcomes
Hussain, 2007 | Retrospective, Case-Control (Case = post ERCP major bleeding) | Academic, Multi Site | Canada | 126 | Endoscopy | NR | Created variable for APT exposure within 10 days of procedure including ASA, NSAIDs, COX2 inhibitors and P2Y12 inhibitors | | | | Exposure to APT not significantly associated with post procedural bleeding | NR | NR
Jacob, 2014 | Retrospective | Academic, Single Site | United States | 142 | Orthopedics | NR | Clopidogrel (n=142) | Compared those that received dose within 7 days (n=24) to those that held > 7 days (n=118) | | NR | Transfusions: 29% vs 10% for intraoperative; 32 vs 8% within 24 hours; 37 vs 15% for entire hospitalization | MACE: Not statistically different | No difference in readmission or reoperation between groups
Mackinnon, 2008 | Retrospective | Academic, Multi Site | United Kingdom | 135 | Renal Biopsy | NR | ASA (n=122), clopidogrel (n=9), dipyridamole (n=4) | Continued (n=75), held (n=60) | Yes | NA | No difference in major bleeding | NR | NR
McCunniff, 2016 | Retrospective | Academic, Single Site | United States | 454 | Orthopedics | NR | Clopidogrel (n=13), ASA (n=72), No APT (n=369) | All held | Yes | NR | No difference in transfusions | MI, IS, DVT/PE: No events | NR
Radovanovic, 2012 | Retrospective | Academic, Single Site | Ireland | 60 | Orthopedics | Atrial Fibrillation (n=12), DVT (n=4), NR (n=14) | Coumadin (n=20), clopidogrel (n=10), control (n=30) | Stopped | Coumadin 3-5 days until INR <1.4; clopidogrel >=5 days | NR | Transfusions: Warfarin 40% vs 13% control; No difference clopidogrel vs control | NR | NR
Ryan, 2013 | Prospective | Academic, Multi Site | Ireland | 85 | Optho | CAD (n=38), Cerebrovascular disease (n=11), Atrial Fibrillation (n=13), PVD (n=3), Thromboembolic Disease (n=4), Other (n=11) | DAPT (n=11), Plavix (n=8), ASA (n=77), Warfarin (n=11) | Continue | NA | NA | Type of APT or anticoagulant not a significant risk factor for intraoperative or postoperative bleeding | NR | NR
Strosberg, 2016 | Retrospective | Academic, Single Site | United States | 200 | General, Thoracic, Vascular | Coronary stent (n=75), peripheral stent (n=58), IS (n=34) | Clopidogrel (n=200), 143 of those on DAPT | Compared those that received clopidogrel within 5 days (n=88) to those that held > 5 days (n=112) | | NR | No difference in perioperative transfusion | No difference in MI, IS, ALI, visceral ischemia | No difference in 30 day mortality
Toepfer, 2013 | Retrospective | Academic, Single Site | United States | 624 | Minor Urology | MI (n=39), IS (n=9), Afib (n=6), PE/DVT (n=7) | DAPT (n=13), clopidogrel (n=4), ASA (n=137), Controls (n=470) | Compared patients who received APT within 2 days of surgery to patients not on APT or on APT but discontinued >5 days; patients who received dose between 2-5 days were excluded | | NR | No difference in urinary clot retention | No difference in stroke MI, DVT, PE | No difference in mortality, 30 day readmission, reoperation

ALI = Acute limb ischemia, ASA = Aspirin; APT = Antiplatelet; CABG = Coronary Artery Bypass Graft; DVT = Deep Vein Thrombosis; ERCP = Endoscopic Retrograde Cholangio-Pancreatography; IS = Ischemic Stroke; MACE = Major Adverse Cardiac Event; MI = Myocardial Infarction; NSAID = Non-steroidal anti-inflammatory; Optho = Ophthalmology; PCI = Percutaneous Coronary Intervention; PE = Pulmonary Embolus | NA = Not applicable; NR = Not Recorded