# APPENDIX B PEER REVIEW COMMENTS/AUTHOR RESPONSES

Comment | Response
I found one typo, there is no space between “13studies”. It is throughout the manuscript. Search and replace on “13studies” and make it “13 studies”. I am disappointed that nothing could be concluded. The management of anti-platelet therapy is a major concern. We spend a lot of thought on it and finding that the evidence for our approaches is non-existent is disappointing. We must be doing something approximately correct as we seem to have reduced the number of catastrophes from APT management choices and surgery, but the evidence for our approaches is clearly non-existent. | The change has been made from “13studies” to “13 studies”.
The review was straightforward and understandable, though of course limited due to lack of available literature to address the questions posed. That said, it articulated the issues (and lack of evidence) well. I found one typo on page 18, line 15: lacks” should be “lack”. Otherwise I have no comments | The change has been made from “lacks” to “lack”.
This will be an important publication and clearly outlines a large gap in our understanding of how best to manage high-risk patients with vascular disease. Minor points for revision:; 1. Should key question 1 be changed from, “undergoing elective non-cardiac surgical procedures” to “undergoing elective non-cardiac surgery”? Or, should the title be changed to end in ‘Surgical Procedures” rather than “Surgery.”; 2. Line 10: procedures in its first instance is misspelled; 3. Would consider replacing phrase, “cerebrovascular accident” with, “Ischemic stroke.”; 4. Under ‘Data Synthesis and Analysis,’ Methods section: Consider placing either eg, or ie, in the phrase, “setting (academic, community, Veterans Affairs) | Unfortunately we are unable to change the title or key questions at this point; however, we did find an inconsistency in the language between the abstract and main body of the text that has been resolved. Thank you for the other recommendations. We have changed “cerebrovascular accident” to “ischemic stroke” throughout the report, and we have added “eg,” in the phrase, “setting (academic, community, Veterans Affairs)”.
There is clearly a lack of reported data on the managemtn of perioperative APT with peripheral stents. Clinicians generally manage APT baseD on the type of stents and the duration after implantation. Most vascular surgeons will operate on ASA alone as a bridging agent. Stent thrombosis is antecdotally low in this circumstance. Validation of these guidelines could be accomplished by retrospective reporting of outcomes based on these clinical guidelines. The VA is an ideal environment for such reporting, although clinical interest is relatively low. A randomized trial of this research question would require a large sample size (as mentioned) and has a low clinical impact. | This is a good point that we have incorporated into our research gaps/future research discussion. Given the size and quality of studies that currently exist, even a well-constructed observational study would have significant merit and may be more pragmatic in the event an RCT is never considered.