# APPENDIX A SEARCH STRATEGIES

## Database searched and time period covered:

PubMed – From inception to 10/18/2016

Language:

English

Search strategy:

platelet aggregation inhibitors[mh] OR antiplatelet therap* OR anti-platelet therap*

AND

surgery OR surgical

AND

elective

Limited to English