# SUMMARY AND DISCUSSION

The overarching finding from this systematic review is that the available evidence regarding perioperative antiplatelet management in patients with cardiac stents undergoing non-emergent surgery is insufficient to conclusively guide clinical practice. Study heterogeneity, combined with small sample sizes, limited the ability to assess the impact of the different aspects of APT – timing of cessation, bridging, restarting therapy, and type of APT. Additionally, the varied range of invasiveness of the procedure, from skin excisions to major thoracic cases, contributes to the operative bleeding risk and MACE, yet many studies lacks sufficient detail to assess the impact of procedure on the outcomes. It is also likely that factors other than perioperative APT may be in part responsible for differences in bleeding and MACE rates observed between studies.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question 1

Thirteen observational studies reported the details of preoperative APT, perioperative anti-platelet therapy management, and outcomes, in sufficient detail to assess their association. The majority of studies were small, with fewer than 100 patients included, and the results were quite heterogeneous, with MACE rates and bleeding rates varying many-fold between studies reporting outcomes for the same combination of preoperative APT and perioperative management (such as preoperative dual antiplatelet therapy, holding both prior to surgery). In general, within studies the bleeding outcomes were reported at higher rates than the MACE outcomes.

### Key Question 2

Evidence for the impact of timing of discontinuation of APT consists of very small case reports within larger studies, and demonstrated no identifiable trend. In the VA case control study discussed above,^22^ there was no association between stopping dual APT for at least 5 days versus some other strategy.

### Key Question 3

Few studies reported results stratified by type of surgical procedure, and among those that did there was no clear signal of differences in outcomes depending on perioperative antiplatelet strategy.

### Key Question 4

One large VA study did not find any evidence that the type of APT was associated with differences in MACE outcomes.

### Key Question 5

Evidence for the impact of timing of resuming APT was absent from the identified literature.

## LIMITATIONS

The primary limitation for this systematic review is the quantity and quality of the available evidence. Numerous studies of APT in the perioperative period were excluded because details of the antiplatelet therapy were not presented in sufficient detail. Given the heterogeneity observed, the data suggest that variables other than the antiplatelet strategy may play a role in determining perioperative bleeding or MACE rates, and in most cases these other variables were not identified or not adequately able to be controlled for in these observation studies.

We theorize that several factors may work in conjunction and be associated with bleeding and MACE events, but the data were too limited to help address this. For example, it is likely that the type of APT and the invasiveness of the operation combined may be associated with bleeding and MACE. However, the majority of studies included a wide range of procedures (skin excision through to thoracic surgery) and the APT management also varied between studies (timing, dual versus single preoperative, cessation versus continuing, and use of bridging). Additionally, the outcomes and APT management were often only reported for cases where an event occurred, thus the management of those without an event was unknown. This prevented us from identifying whether one APT management for a particular type of procedure, or group of procedures, was protective or harmful. Another possibility is that whether or not the patients' cardiac status was optimized or if they were satisfactorily cleared from a cardiac standpoint was absent from the studies. For example, we could not assess the adequacy of their level of beta blockade, functional status, or cardiac function at the time of surgery. Additionally, perioperative management can also impact development of MACE, such as fluid management, which was not reported in the studies.

### Publication Bias

Publication bias is always a concern in any systematic review. We had too few studies to conduct statistical tests for the possible presence of publication bias, so we cannot provide a data-based estimate of its likelihood.

### Study Quality

Overall, the quality of the evidence was insufficient to support strong conclusions across the 4 key questions.

### Heterogeneity

Heterogeneity is a major limitation of this systematic review, as the variation in reported MACE and bleeding outcomes between studies was large and did not suggest a pattern between perioperative antiplatelet management and outcomes.

### Applicability of Findings to the VA Population

Several studies specifically assessed Veterans, including the largest study. Even though the remaining studies were not in VA populations, we judged these results as being moderately or even strongly applicable to VA since the enrolled patients with cardiac stents were very likely to moderately or strongly resemble VA patients, except with respect to gender.

## RESEARCH GAPS/FUTURE RESEARCH

There is obviously a very large research gap, as we were unable to find evidence sufficient to reach conclusions for any of the key questions. The evidence does suggest that differences in outcomes due to perioperative antiplatelet management are likely to be smaller than differences in outcomes due to other clinical factors. This in turn suggests that observational studies are going to have difficulty in identifying or balancing these other clinical factors, rendering additional observational studies of limited value in reaching strong conclusions about perioperative antiplatelet management strategies. Randomized studies would balance these other clinical factors, even if they could not be identified. Yet randomized studies present their own problem – namely sample size. Trying to detect small effects requires large samples. For example, if the rate of MACE outcomes is 5% if both dual antiplatelet agents are stopped, then in order for a clinical trial to have 80% power to detect a decrease in MACE outcomes to 3% if dual antiplatelet therapy is continued would require a sample size of almost 1500 patients in each arm. Similarly, if the rate of bleeding is 5% with all APT stopped, then it would require more than 400 patients in each arm to have 80% power to detect a doubling of this to 10% if dual antiplatelet therapy is continued. While these sample sizes are not unprecedented in cardiology research, they are nevertheless much larger than any of the observational studies included in this review (counting the case-control portion of the VA study by Hawn and colleagues). And if any additional stratifying variables are included, such as type of surgery, or timing of ATP stopping and resumption, this would greatly add to the needed sample size. Nevertheless, if stronger evidence is desired, rather than continue to conduct observational studies of limited ability to provide definitive conclusions, investing in a definitive RCT may be more cost-effective.

## CONCLUSIONS

Published studies of the association between perioperative antiplatelet therapy management and outcomes in patients with coronary stents undergoing non-emergent surgery have challenging methodologic limitations and heterogeneous results, and do not provide sufficient evidence to moderately or strongly support any clinical recommendation. The results suggest that clinical factors other than perioperative APT management may be more responsible for MACE and bleeding outcomes. It is likely that a clinical trial of large size would be needed to more definitely provide evidence about this clinical decision.