# RESULTS

## LITERATURE FLOW

Our literature searches and reference mining identified 4,068 potentially relevant citations, of which 491 were included by at least one reviewer at the title screening. Of these, 100 abstracts were included and obtained as full-text publications. A total of 14 publications were identified that contributed as includes to our final sample. The 86 excluded studies from the full-text review were excluded for the following reasons: the study design was a case series less than 10, systematic review, non-systematic review, did not present original data, or was only relevant as background material (n = 29); no elective non-cardiac surgery outcomes were reported separately in the data (n = 23); no patients post-PCI were reported in the data (n = 20); or inadequate details were given on the APT management (n = 14). See Figure 1 for literature flow. Details of included studies are provided in Appendix C. A full list of those studies excluded from the full-text review is included in Appendix D.

Figure 1 Literature Flow Chart

* Search results were combined from Scopus, Web of Science, and PubMed. Reference mining identified 9 articles, also included in this number. See Appendix A for details.

** Manuscript reference list includes additional references cited for background and methods plus websites relevant to key questions.

## KEY QUESTION 1 Among patients on APT in conjunction with PCI undergoing elective surgical procedures, including intraocular procedures, what are the benefits and harms of holding APT prior to surgery?

We identified 13 studies meeting all the eligibility requirements. None were clinical trials. Twelve of these were cohort studies, and of these 2 were prospective and 11 were retrospective. One study used a case control design and will be discussed separately. Among the cohort studies, most were small, with 5 reporting on fewer than 50 patients, another 4 reporting on 50-150 patients, and 3 studies reporting on more than 150 patients. The quality of studies was variable: most studies included all or a representative sample of eligible patients and used medical records to assess outcomes, but methods for assessing and adjusting for differences in other clinical variables were very heterogeneous (Table 1). We also included 1 study that did not meet all eligibility criteria, because it was the only identified study that assessed intraocular procedures.

Table 1 Quality Assessment for Included Studies

Author, year | Study design | Sample representativeness | Assessment of outcomes | Follow-up rate | Address balancing for sample differences | Statistical methods used
Alshawabkeh et al, 2013^13^ | ● | ■ | ■ | N/A | ♦ | N/A
Marcos et al, 2011^14^ | ● | ■ | ■ | N/A | ♦ | N/A
Yamamoto et al, 2014^15^ | ● | ■ | ■ | N/A | ♦ | N/A
Tanaka et al, 2014^16^ | ● | ■ | ■ | N/A | ♦ | N/A
Sonobe et al, 2011^17^ | ● | ● | ♦ | N/A | ♦ | N/A
Cerfolio et al, 2010^18^ | ■ | N/A | ■ | ■ | ■ | ■
Ryan et al, 2013^19^ | ■ | N/A | ■ | ■ | ■ | ■
Capodanno et al, 2015^20^ | ● | ■ | ■ | N/A | ■ | ■
Bolad et al, 2011^21^ | ● | ■ | ■ | N/A | ■ | ●
Hawn et al, 2013^22^ | ● | ■ | ■ | N/A | ■ | ■
Assali et al, 2009^23^ | ● | ■ | ■ | N/A | ● | ●
Brotman et al, 2007^24^ | ● | ■ | ■ | N/A | ■ | ●
Choi et al, 2010^25^ | ■ | ■ | ■ | ■ | ■ | ●
Conroy et al, 2007^26^ | ● | ■ | ■ | N/A | ♦ | ♦

Study design: prospective = square, retrospective = circle

Sample representativeness: all patients/consecutive sample = square, not reported/unclear = circle

Assessment of outcomes: medical record review = square, administrative data = circle, unclear = diamond

Follow-up rate: > 80% = square, 60% - 80% = circle, < 60% = diamond

Address balancing of sample differences: yes = square, no = diamond

Statistical methods used: measurable methods = square, univariate methods = circle

Figure 2 presents the outcomes reported in the cohort studies, by the preoperative APT (dual, single, or none) and the perioperative management (stop both, stop one – which almost always meant stopping clopidogrel, stop one plus “bridge” the patient with another agent designed to reduce thrombosis (such as tirofiban), or continue both). In Figure 2, each study is given equal weight, regardless of sample size. Figure 3 presents the same results, but now the size of the mark for each study is proportional to the sample size, so that studies with larger samples are given more visual “weight.” No clear pattern is apparent, as the reported outcomes vary as much across studies of “the same management” as across the different perioperative management choices. So, for example, 4 studies reported 0% MACE rates representing 3 different APT strategies. Further, among the studies that used DAPT pre-operatively, the study with the highest MACE event rate (21.4%) continued SAPT, whereas the studies that stopped both agents had less than half the MACE rates (11.1% and 2.3%). For bleeding, 3 studies reported 0% rates representing 3 different APT strategies. The highest rate (14.8%) was reported in a study where both agents were stopped perioperatively. Further complicating the interpretation is that almost all of these studies were small, with sample sizes within stratum of 17, 63, 51, 14, 10, and 27 and reporting very few events (actual numbers of MACE events reported were 2, 0, 2, 3, 2, and 3. Thus, from these data it is impossible to support a conclusion that a particular management strategy is associated with fewer MACE and bleeding outcomes compared to some other management strategy.

Figure 2 Outcomes of observational studies of preoperative antiplatelet therapy, perioperative APT management, and outcomes (unweighted)

Figure 3 Outcomes of observational studies of preoperative antiplatelet therapy, perioperative APT management, and outcomes (weighted by sample size)

We next discuss here the case-control study, which is also the largest study and used sophisticated statistical techniques. ^22^ This study had 2 components. The first component was a retrospective cohort of 41,989 Veterans Affairs patients who underwent noncardiac surgery within 24 months of stent placement. Findings from an analysis of variables predicting MACE outcomes within 30 days showed that nonelective surgery, recent myocardial infarction (< 6 months), elevated cardiac risk index, the presence of heart failure, age, the presence of chronic kidney disease, and type of operation were all associated with increased risk. The second component of the study was focused on antiplatelet management and used a case-control design. Investigators abstracted from the medical records of 369 cases the specific details of preoperative and perioperative antiplatelet therapy management. A MACE occurred in 284 cases and did not occur in 85. There was no association of perioperative antiplatelet therapy and proportion of patients with a MACE. For example, in patients who were on dual antiplatelet therapy preoperatively there was no difference between persons who had a post-operative MACE and those that did not in the proportions who had all therapy continued (67.1% vs 64.6%), if only clopidogrel was held (9.4% vs 12.7%) or if both antiplatelet agents were held (19.4% vs 18.4%). Similar results were seen for patients who were on SAPT preoperatively, and whether therapy was or was not held for at least 5 days prior to surgery. These results are consistent with the results presented from the individual cohort studies that there is insufficient evidence to conclude that there is a strong or moderate relationship between perioperative antiplatelet management strategy and post-operative MACE.

### Summary of Findings

Thirteen observational studies reported the details of preoperative APT, perioperative APT management, and outcomes in sufficient detail to assess their association. The majority of studies were small, with fewer than 100 patients included, and the results were quite heterogeneous, with MACE rates and bleeding rates varying many-fold between studies reporting outcomes for the same combination of preoperative APT and perioperative management (such as preoperative DAPT, holding both prior to surgery). In general, within studies the bleeding outcomes were reported at higher rates than the MACE outcomes.

### Quality of Evidence for Key Question 1

We judged the quality of evidence as insufficient in terms of specifying a particular preferred perioperative antiplatelet management that minimized MACE events and bleeding.

## KEY QUESTION 2 How does benefit/risk vary by the timing of discontinuation?

The timing of discontinuation of APT cessation varied between studies and among individual patients within studies. Most studies in which APT was discontinued preoperatively reported either a median or range of days of preoperative discontinuation. For the majority of these studies, antiplatelet agents were discontinued between 3 and 10 days preoperatively, but no rationale for this timing was provided. One study did note that cardiologist recommendations influenced the duration of preoperative APT cessation.^17^

No included study systematically assessed the impact of timing of APT cessation on any clinical outcomes. Three studies provided limited case reports on a small subset of patients with MACE or bleeding outcomes,^17,23,24^ but no trend was evident in any of these case reports for the impact of timing of APT cessation.

### Summary of Findings

Evidence for the impact of timing of discontinuation of APT consists of very small case reports within larger studies, and demonstrated no identifiable trend. In the VA case-control study discussed above,^22^ there was no association between stopping APT for at least 5 days versus some other strategy.

### Quality of Evidence for Key Question 2

We judged the quality of evidence as insufficient regarding the timing of discontinuation of APT prior to surgery.

## KEY QUESTION 3 How does benefit/risk vary by type of surgical procedure, including intraocular procedures?

Most studies included a mix of different types of surgical procedures, and did not stratify their outcome results by type of case and details of the antiplatelet management. We did identify 3 studies that were either about only cases our surgeon team members judged as all major or all minor, or which presented stratified results.^15,17,18^

Figure 4 and Figure 5 present the results of the MACE and bleeding outcomes in these studies. Figure 4 presents the results for each study with equal weight. Figure 5 presents the results for studies with the size of the mark proportion to the sample size, so that larger studies are given more visual “weight.” No clear pattern is apparent. In the study by Yamamoto,^15^ which was of major surgery, there were no MACE outcomes reported in any group defined by antiplatelet strategy, but there was higher reported bleeding if dual APT was continued or if the patient received bridging therapy. Another study of major surgery^17^ also reported no MACE outcomes in patients who were on single antiplatelet therapy that was stopped prior to surgery. However, another study of patients on single APT prior to major surgery did report a nearly 5% rate of MACE, despite continuing the patients on antiplatelet therapy. The one study that included only patients with minor surgical procedures reported a MACE rate of about 2.5%, which occurred in patients on dual APT in which one agent was stopped. Thus, we could discern no pattern in these data to indicate whether the perioperative antiplatelet management strategy should vary depending on the type of surgical procedure.

Figure 4 Outcomes of observational studies of preoperative antiplatelet therapy, perioperative APT management, and outcomes by surgery risk category (unweighted)

Figure 5 Outcomes of observational studies of preoperative antiplatelet therapy, perioperative APT management, and outcomes by surgery risk category (weighted by sample size)

There were no studies of ophthalmologic surgery that met inclusion criteria. The only study of antiplatelet management and ocular procedures that we identified was a prospective study of 85 patients taking antiplatelet or anticoagulant therapy and undergoing 107 vitreoretinal procedures (of which 88% of cases were vitrectomies).^19^ Patients were taking antiplatelet or anticoagulant therapy for a diversity of reasons; only 13% of patients had cardiac stents. Thus, this study would have been excluded on the grounds of being the wrong patient population. Nevertheless, as it is the only study of ophthalmologic procedures we identified, we summarize the results here. Among the 107 cases, in 72% the patients were taking aspirin alone, in 8% taking clopidogrel alone, and in 10% each were taking aspirin and clopidogrel or warfarin. All patients had their antiplatelet or warfarin therapy continued during the perioperative period. The primary outcome was intraoperative or postoperative bleeding. No MACE outcomes were reported. There were 25 cases of intraoperative bleeding, of which 24 happened during vitrectomy. Of these 24, 22 were hemorrhage in the vitreous cavity, of which 20 were classified as “mild” and one each was classified as “moderate” and “dense.” There were 24 cases of post-operative bleeding, of which 22 followed vitrectomy and 2 followed scleral buckling. Among the vitrectomy cases, there were 12 cases of mild-to-moderate vitreous cavity hemorrhage, and 5 cases of dense hemorrhage. There were 4 cases of anterior chamber hemorrhage, and one choroidal hemorrhage. The 2 cases following scleral buckling consisted of one case each of a subretinal hemorrhage and a choirodal hemorrhage. There were no cases of catastrophic suprachoroidal hemorrhage leading to loss of vision. The authors concluded that continuing these medications during the perioperative period is safe for vitreoretinal surgery.

### Summary of Findings

Few studies reported results stratified by type of surgical procedure, and among those that did there was no clear signal of differences in outcomes depending on perioperative antiplatelet strategy.

### Quality of Evidence for Key Question 3

We judged the evidence as insufficient regarding the relationship between perioperative antiplatelet strategy and outcomes depending on the type of surgical procedure.

## KEY QUESTION 4 How does benefit/risk vary by type of APT?

Among the 5 studies that included more than 100 patients, one was primarily focused on a bridging strategy,^20^ 2 studies did not assess outcome differences by type of APT,^16,24^ and one study only assessed differences between single antiplatelet therapy versus dual antiplatelet therapy.^15^ Only the case-control study by Hawn and colleagues (done in a VA setting) assessed outcomes by particular type of antiplatelet management.^22^ In that study, there was no statistically significant difference in the proportions of patients with and without MACE outcomes whether they had aspirin or clopidogrel both continued or both stopped perioperatively (for patients on DAPT), or one or the other held, or for patients on SAPT whether it was aspirin or clopidogrel and whether it was continued or stopped. Thus, there was no evidence that the type of antiplatelet therapy or its perioperative management was related to difference in MACE outcomes, although some categories included relatively few numbers of patients and therefore had relatively low statistical power to detect differences (such as only 33 patients who were taking only clopidogrel preoperatively, and only 14 patients who were on dual therapy that had only the aspirin held).

### Summary of Findings

One large VA study did not find any evidence that the type of APT was associated with differences in MACE outcomes.

### Quality of Evidence for Key Question 4

We judged the evidence as insufficient regarding the association between the type of APT and outcomes, as there is only a single study for MACE outcomes and no study that assessed bleeding outcomes.

## KEY QUESTION 5 How does benefit/risk vary by the timing of resuming APT?

The timing of resumption of APT after perioperative cessation varied between studies and among individual patients within studies. Most studies reported resuming APT as soon as possible after surgery. Cited rationales for timing of resuming APT therapy included clinical assessment of bleeding risk^14^ and discretion of the surgical team.^13^

No included study systematically assessed the impact of timing of resuming APT on any clinical outcomes.

### Summary of Findings

Evidence for the impact of timing of resuming APT was absent from the identified literature.

### Quality of Evidence for Key Question 5

We judged the evidence as insufficient regarding the timing of resumption of APT.