# REFERENCES

1 Kaluza GL, Joseph J, Lee JR, Raizner ME, Raizner AE. Catastrophic outcomes of noncardiac surgery soon after coronary stenting. Journal of the American College of Cardiology. Apr 2000;35(5):1288-1294.10758971
2 Wilson SH, Fasseas P, Orford JL Clinical outcome of patients undergoing non-cardiac surgery in the 2 months following coronary stenting. Journal of the American College of Cardiology. Jul 16 2003;42(2):234-240.12875757
3 McFadden EP, Stabile E, Regar E Late thrombosis in drug-eluting coronary stents after discontinuation of antiplatelet therapy. The Lancet. 2004;364(9444):1519-1521.
4 Fleisher LA, Fleischmann KE, Auerbach AD 2014 ACC/AHA Guideline on Perioperative Cardiovascular Evaluation and Management of Patients Undergoing Noncardiac Surgery. Journal of the American College of Cardiology. Dec 2014;64(22):E77-E137.25091544
5 Singla S, Sachdeva R, Uretsky BF. The risk of adverse cardiac and bleeding events following noncardiac surgery relative to antiplatelet therapy in patients with prior percutaneous coronary intervention. Journal of the American College of Cardiology. Nov 13 2012;60(20):2005-2016.23083781
6 van Kuijk JP, Flu WJ, Schouten O Timing of noncardiac surgery after coronary artery stenting with bare metal or drug-eluting stents. The American journal of cardiology. Nov 1 2009;104(9):1229-1234.19840567
7 Albaladejo P, Marret E, Samama CM Non-cardiac surgery in patients with coronary stents: the RECO study. Heart (British Cardiac Society). Oct 2011;97(19):1566-1572.21791513
8 Buszman PP, Orlik B, Trela B Comparable clinical safety and efficacy of biodegradable versus durable polymer paclitaxel eluting stents despite shorter dual antiplatelet therapy: insights from a multicenter, propensity score-matched registry. Catheterization and cardiovascular interventions : official journal of the Society for Cardiac Angiography & Interventions. Sep 1 2013;82(3):E155-162.23109067
9 Scacciatella P, D'Amico M, Meynet I Rationale and results of percutaneous coronary revascularization with endothelial progenitor cell capture stent in high-risk patients requiring undeferrable non-cardiac surgery. Minerva cardioangiologica. Oct 2011;59(5):411-418.21730938
10 Briguori C, Visconti G, De Micco F, Focaccio A. The avantgarde carbostent in patients scheduled for undelayable noncardiac surgery. Thrombosis. 2012;2012:372371.22448320
11 Higgins JP, Altman DG, Gøtzsche PC The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ (Clinical research ed.). 2011;343:d5928.
12 GRADE working group. 2014; http://www.gradeworkinggroup.org/. Accessed 09/25/15.
13 Alshawabkeh LI, Prasad A, Lenkovsky F Outcomes of a preoperative “bridging” strategy with glycoprotein IIb/IIIa inhibitors to prevent perioperative stent thrombosis in patients with drug-eluting stents who undergo surgery necessitating interruption of thienopyridine administration. EuroIntervention : journal of EuroPCR in collaboration with the Working Group on Interventional Cardiology of the European Society of Cardiology. Jun 22 2013;9(2):204-211.
14 Marcos EG, Da Fonseca AC, Hofma SH. Bridging therapy for early surgery in patients on dual antiplatelet therapy after drug-eluting stent implantation. Netherlands heart journal : monthly journal of the Netherlands Society of Cardiology and the Netherlands Heart Foundation. Oct 2011;19(10):412-417.
15 Yamamoto K, Wada H, Sakakura K Cardiovascular and bleeding risk of non-cardiac surgery in patients on antiplatelet therapy. Journal of cardiology. Nov 2014;64(5):334-338.24802171
16 Tanaka A, Sakakibara M, Ishii H The risk of adverse cardiac events following minor surgery under discontinuation of all antiplatelet therapy in patients with prior drug-eluting stent implantation. International journal of cardiology. Mar 2014;172(1):E125-E126.24433617
17 Sonobe M, Sato T, Chen F Management of patients with coronary stents in elective thoracic surgery. General thoracic and cardiovascular surgery. Jul 2011;59(7):477-482.21751107
18 Cerfolio RJ, Minnich DJ, Bryant AS. General thoracic surgery is safe in patients taking clopidogrel (Plavix). The Journal of thoracic and cardiovascular surgery. Nov 2010;140(5):970-976.20804992
19 Ryan A, Saad T, Kirwan C, Keegan DJ, Acheson RW. Maintenance of perioperative antiplatelet and anticoagulant therapy for vitreoretinal surgery. Clinical & experimental ophthalmology. May-Jun 2013;41(4):387-395.23094982
20 Capodanno D, Musumeci G, Lettieri C Impact of bridging with perioperative low-molecular-weight heparin on cardiac and bleeding outcomes of stented patients undergoing non-cardiac surgery. Thrombosis and haemostasis. Aug 2015;114(2):423-431.26017898
21 Bolad IA, Alqaqa'a A, Khan B Cardiac events after non-cardiac surgery in patients with previous coronary intervention in the drug-eluting stent era. The Journal of invasive cardiology. Jul 2011;23(7):283-286.21725123
22 Hawn MT, Graham LA, Richman JS, Itani KM, Henderson WG, Maddox TM. Risk of major adverse cardiac events following noncardiac surgery in patients with coronary stents. Jama. Oct 9 2013;310(14):1462-1472.24101118
23 Assali A, Vaknin-Assa H, Lev E The risk of cardiac complications following noncardiac surgery in patients with drug-eluting stents implanted at least 6 months before surgery. Catheterization and cardiovascular interventions : official journal of the Society for Cardiac Angiography & Interventions. Nov 15 2009;74(6):837-843.19626693
24 Brotman DJ, Bakhru M, Saber W Discontinuation of antiplatelet therapy prior to low-risk noncardiac surgery in patients with drug-eluting stents: a retrospective cohort study. Journal of hospital medicine. Nov 2007;2(6):378-384.18081175
25 Choi CU, Rha SW, Jin Z The optimal timing for non-cardiac surgery after percutaneous coronary intervention with drug-eluting stents. International journal of cardiology. Mar 18 2010;139(3):313-316.19073354
26 Conroy M, Bolsin SN, Black SA, Orford N. Perioperative complications in patients with drug-eluting stents: a three-year audit at Geelong Hospital. Anaesth Intensive Care. Dec 2007;35(6):939-944.18084986