# METHODS

## TOPIC DEVELOPMENT

This topic was developed in response to a nomination by Dr. Arthur Wallace, Chief of Anesthesia at the San Francisco VAMC, and by Dr. Christina Matadial of the Miami VAHCS. Key questions were then developed with input from the topic nominators, the ESP Coordinating Center, the review team, and the technical expert panel (TEP).

The key questions were:

1. Among patients on antiplatelet therapy (APT) in conjunction with percutaneous coronary intervention (PCI) undergoing elective surgical procedures, including intraocular procedures, what are the benefits and harms of holding APT prior to surgery?
2. How does benefit/risk vary by the timing of discontinuation?
3. How does benefit/risk vary by type of surgical procedure, including intraocular procedures?
4. How does benefit/risk vary by type of APT?
5. How does benefit/risk vary by the timing of resuming APT?

The review was registered in PROSPERO: CRD42016036607.

## SEARCH STRATEGY

We conducted searches in PubMed, Web of Science, and Scopus from inception of each database to 12/17/2015 (see Appendix A for full search strategy). One of the searches in PubMed used a broad set of terms relating to APT, percutaneous coronary intervention (PCI), and discontinuing therapy. In addition, searches were run in all 3 databases looking for articles related to 3 key references.^5,6,7^ We also reference mined key existing non-systematic review articles.^8^

## STUDY SELECTION

Four team members, working in pairs, independently screened the titles of retrieved citations. Citations deemed relevant by at least one reviewer were then screened at the abstract level by 2 independent reviewers. Any disagreements were resolved by consensus decision after study team discussion. To be included at the abstract stage, abstracts needed to include: 1.) That the patients underwent elective, non-cardiac surgery, either entirely or in the great majority of reported cases; 2.) That the patients were post-percutaneous coronary intervention with stent placement; 3.) That the article presented original data (eg, not a review, commentary, or duplicate publication using the same data as another included publication); 4.) That the article reported major adverse cardiac events (MACE) as a composite or any of the individual components (such as stent closure) or bleeding outcomes; and 5.) That the article was published in the English language. Any abstracts with ambiguity on these criteria were included for full-text review.

All included abstracts were then obtained as full text. Full-text publications were screened in duplicate against the same pre-specified eligibility criteria as for the abstract screen, as well as the additional criteria that the publication could not report on a case series of under 10 patients, the stents being used had to be available in the US (which excluded studies of stents coated with endothelial progenitor cells^9^ or carbofil coating,^10^ and that the elective non-cardiac surgery outcomes had to be reported separately. At this stage, each article was carefully examined to make sure the details of the preoperative antiplatelet therapy and the perioperative antiplatelet management were described relative to the outcomes that were reported. We did not exclude studies based on the type of APT management (ie, all P2Y12 agents were eligible). Studies that did not report these details were excluded. So, for example, a hypothetical study that stated they assessed 100 patients who were on dual APT for a drug-eluting stent, and both antiplatelet agents were stopped 5 days prior to surgery “in 85% of cases, with the remainder continuing aspirin through surgery,” and then reported major adverse cardiac events and serious bleeding, would be excluded since there was no way to know whether the adverse events happened in the patients who had both APT agents stopped or in the few patients who were continued on aspirin. Ergo, unless we could match the reported outcomes to the exact preoperative and perioperative APT, we were forced to exclude the study. Any disagreements were resolved by consensus decision after discussion with the study team.

The following PICOTS framework describes our inclusion criteria:

Participants/population: Patients on APT in conjunction with PCI undergoing elective surgical procedures including intraocular procedures and procedures requiring anesthesiologist (eg, some forms of endoscopy, but not dental procedures).

Intervention(s): Stopping all or some APT, bridging therapy.

Comparators: Not stopping or stopping at different times relative to the PCI or to the surgical procedure, as well as by drug.

Outcomes: Thrombotic outcomes, hemorrhagic outcomes, death, disability, major adverse cardiac events (MACE).

Timing: There was no restriction on timing, but the majority of studies (10/13) included outcomes measured within 30 days of surgery.

Setting: All patients were hospitalized undergoing surgery.

## DATA ABSTRACTION

Data extraction was completed in duplicate. All discrepancies were resolved with full group discussion. We abstracted data on the following: sample size, surgical procedures, number of centers included, cardiac stent types, preoperative antiplatelet management, antiplatelet management at surgery, APT cessation, whether bridging therapy was included, outcomes assessed and instruments used for outcomes, outcome follow-up time period, whether the study took place in an academic setting, country, mean age of patients, percent female patients, patient comorbidities, sampling method in retrospective studies, and whether the article addressed balancing for sample differences in cohort studies. MACE were usually defined as death, stent thrombosis, or myocardial infarction, and occasionally other outcome. If a study reported only one these outcomes (for example, stent thrombosis) we included it as MACE. Hemorrhagic outcomes were reported much more variably, from wound hematoma to blood loss requiring transfusion of 1 or more units of blood. We did not include the former, but did include the latter, in our abstraction of hemorrhagic outcomes. Specifically, we abstracted bleeding events that the surgeons on the study team deemed clinically significant, which included the need for blood transfusion, re-operation, or blood loss leading to an escalation of care. Minor wound hematomas were not included, for example.

## QUALITY ASSESSMENT

We had planned on assessing any randomized controlled trials with the Cochrane Risk of Bias tool.^11^ However, we identified no trials. Cohort studies were assessed on design (eg, retrospective vs prospective), representativeness of the enrolled subjects, assessments of the exposure and outcome, follow-up rates, and statistical methods.

## DATA SYNTHESIS

Data were too heterogeneous to support statistical pooling. We plotted MACE and bleeding outcomes by the preoperative APT and the perioperative management, and assessed for trends or patterns. We then assessed possible explanations for the observed heterogeneity by stratifying studies based on the types of surgical procedures included (major, such as thoracic surgery, versus minor, such as endoscopy, skin procedures), and by the duration of time between stent placement and surgery (using 6 months as the threshold, or the time closest to 6 months).

## RATING THE BODY OF EVIDENCE

Where possible a summary of findings and quality of evidence table was used to summarize the existing evidence. Based on the GRADE working group,^12^ the quality of the evidence was categorized as follows:

High: We are very confident that the true effect lies close to that of the estimate of the effect.

Moderate: We are moderately confident in the effect estimate: The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.

Low: Our confidence in the effect estimate is limited: The true effect may be substantially different from the estimate of the effect.

Very low: We have very little confidence in the effect estimate: The true effect is likely to be substantially different from the estimate of effect.

GRADE evaluates the quality of the evidence across all identified studies contributing to the outcome of interest.

## PEER REVIEW

A draft version of the report was reviewed by technical experts and clinical leadership. Reviewer comments and our responses are documented in Appendix B.