# INTRODUCTION

The perioperative management of antiplatelet therapy for patients with coronary stents remains unclear. Patients who have coronary stents placed are at risk of stent thrombosis, and therefore are nearly all recommended to receive prolonged antiplatelet therapy: dual antiplatelet therapy (aspirin plus a P2Y12 inhibitor) for a shorter time (such as 30 days, if a bare metal stent was placed) or a longer time (such as 6 months or a year or indefinitely, if a drug-eluting stent was placed); followed by indefinite single antiplatelet therapy (almost always aspirin). Historically, clopidogrel and aspirin has been prescribed. But use of newer agents such as ticagrelor and prasugrel are increasing. Patients undergoing non-cardiac surgery with prior history of percutaneous coronary intervention and placement of coronary stents or balloon angioplasty are at increased risk of perioperative cardiac events.^1^ The risk of perioperative adverse events (ie, major adverse cardiac event, bleeding) is associated with time from percutaneous coronary intervention, operative urgency, and antiplatelet therapy.^2,3^

Current guidelines from the American College of Cardiology (ACC) and American Heart Association (AHA) published in 2014 recommend elective non-cardiac surgery be delayed one year after drug-eluting stent placement, and 30 days after bare metal stent placement.^4^ When considering urgent non-cardiac operative intervention, ACC/AHA recommendations are to continue dual antiplatelet therapy in the perioperative period for 4 to 6 weeks after percutaneous coronary intervention, unless the risks of bleeding outweigh the risks of stent thrombosis.

To help clinicians, patients, and policymakers with this important decision, we conducted a systematic review of the published literature for the following questions. What are the risks and benefits of antiplatelet therapy in the perioperative period after percutaneous coronary intervention? Do the risks and benefits vary by timing of discontinuation and resumption of antiplatelet therapy? And do the risks and benefits vary by operative intervention, or do they vary by type of antiplatelet therapy?