# APPENDIX D CITATIONS FOR EXCLUDED STUDIES

1 Rossini R, Musumeci G, Capodanno D Perioperative management of oral antiplatelet therapy and clinical outcomes in coronary stent patients undergoing surgery. Results of a multicentre registry. Thrombosis and haemostasis. Feb 2015;113(2):272-282.25274620
2 Warshauer J, Patel VG, Christopoulos G, Kotsia AP, Banerjee S, Brilakis ES. Outcomes of preoperative bridging therapy for patients undergoing surgery after coronary stent implantation: a weighted meta-analysis of 280 patients from 8 studies. Catheterization and cardiovascular interventions : official journal of the Society for Cardiac Angiography & Interventions. Jan 1 2015;85(1):25-31.24740634
3 Joo MS, Ahn BM, Kim HJ Evaluation of feasible timing of elective noncardiac procedure after antiplatelet discontinuation in patients treated with antiplatelet agents. Journal of investigative medicine : the official publication of the American Federation for Clinical Research. Jun 2014;62(5):808-812.24569484
4 Kim BK, Yoon JH, Shin DH Prospective and systematic analysis of unexpected requests for non-cardiac surgery or other invasive procedures during the first year after drug-eluting stent implantation. Yonsei medical journal. Mar 2014;55(2):345-352.24532502
5 Mehran R, Baber U, Steg PG Cessation of dual antiplatelet treatment and cardiac events after percutaneous coronary intervention (PARIS): 2 year results from a prospective observational study. Lancet (London, England). Nov 23 2013;382(9906):1714-1722.
6 Singla S, Sachdeva R, Uretsky BF. The risk of adverse cardiac and bleeding events following noncardiac surgery relative to antiplatelet therapy in patients with prior percutaneous coronary intervention. Journal of the American College of Cardiology. Nov 13 2012;60(20):2005-2016.23083781
7 Briguori C, Visconti G, De Micco F, Focaccio A. The avantgarde carbostent in patients scheduled for undelayable noncardiac surgery. Thrombosis. 2012;2012:372371.22448320
8 Scacciatella P, D'Amico M, Meynet I Rationale and results of percutaneous coronary revascularization with endothelial progenitor cell capture stent in high-risk patients requiring undeferrable non-cardiac surgery. Minerva cardioangiologica. Oct 2011;59(5):411-418.21730938
9 To AC, Armstrong G, Zeng I, Webster MW. Noncardiac surgery and bleeding after percutaneous coronary intervention. Circulation. Cardiovascular interventions. Jun 2009;2(3):213-221.20031718
10 Sanchez-Palomino P, Sanchez-Cobo P, Rodriguez-Archilla A Dental extraction in patients receiving dual antiplatelet therapy. Medicina oral, patologia oral y cirugia bucal. Sep 2015;20(5):e616-620.
11 Vlastarakos PV, Sampatakaki A, Kouloumbinis A, Nikolopoulos TP. Perioperative maintenance of dual antiplatelet therapy is safe in patients requiring laser cordectomy for laryngeal cancer. Journal of B.U.ON. : official journal of the Balkan Union of Oncology. May-Jun 2015;20(3):934.26214651
12 Wakabayashi Y, Wada H, Sakakura K Major adverse cardiac and bleeding events associated with non-cardiac surgery in coronary artery disease patients with or without prior percutaneous coronary intervention. Journal of cardiology. Oct 2015;66(4):341-346.25614292
13 Salters C, Bradley B, Charnigo RJ Incidence, nature, and temporal trends of adverse events associated with noncardiac procedures among veterans with drug-eluting coronary artery stents. Catheterization and cardiovascular interventions : official journal of the Society for Cardiac Angiography & Interventions. Aug 2015;86(2):211-219.25323046
14 Bozzani A, Ferlini M, Rossini R Antiplatelet therapy management in patients with coronary stent undergoing vascular surgery. The Journal of cardiovascular surgery. Aug 2015;56(4):681-683.25008060
15 Fujikawa T, Tanaka A, Abe T Does antiplatelet therapy affect outcomes of patients receiving abdominal laparoscopic surgery? Lessons from more than 1,000 laparoscopic operations in a single tertiary referral hospital. Journal of the American College of Surgeons. Dec 2013;217(6):1044-1053.24051069
16 Brilakis ES, Patel VG, Banerjee S. Medical management after coronary stent implantation: a review. Jama. Jul 10 2013;310(2):189-198.23839753
17 Tokushige A, Shiomi H, Morimoto T Incidence and outcome of surgical procedures after coronary bare-metal and drug-eluting stent implantation: a report from the CREDO-Kyoto PCI/CABG registry cohort-2. Circulation. Cardiovascular interventions. Apr 2012;5(2):237-246.22396582
18 van Kuijk JP, Flu WJ, Schouten O Timing of noncardiac surgery after coronary artery stenting with bare metal or drug-eluting stents. The American journal of cardiology. Nov 1 2009;104(9):1229-1234.19840567
19 Rabbitts JA, Nuttall GA, Brown MJ Cardiac risk of noncardiac surgery after percutaneous coronary intervention with drug-eluting stents. Anesthesiology. Oct 2008;109(4):596-604.18813037
20 Nuttall GA, Brown MJ, Stombaugh JW Time and cardiac risk of surgery after bare-metal stent percutaneous coronary intervention. Anesthesiology. Oct 2008;109(4):588-595.18813036
21 Wilson SH, Fasseas P, Orford JL Clinical outcome of patients undergoing non-cardiac surgery in the 2 months following coronary stenting. Journal of the American College of Cardiology. Jul 16 2003;42(2):234-240.12875757
22 Morici N, Moja L, Rosato V Bridge with intravenous antiplatelet therapy during temporary withdrawal of oral agents for surgical procedures: a systematic review. Internal and emergency medicine. Mar 2014;9(2):225-235.24419741
23 Kaluza GL, Joseph J, Lee JR, Raizner ME, Raizner AE. Catastrophic outcomes of noncardiac surgery soon after coronary stenting. Journal of the American College of Cardiology. Apr 2000;35(5):1288-1294.10758971
24 Vicenzi MN, Meislitzer T, Heitzinger B, Halaj M, Fleisher LA, Metzler H. Coronary artery stenting and non-cardiac surgery--a prospective outcome study. British journal of anaesthesia. Jun 2006;96(6):686-693.16670113
25 Ben Morrison T, Horst BM, Brown MJ, Bell MR, Daniels PR. Bridging with glycoprotein IIb/IIIa inhibitors for periprocedural management of antiplatelet therapy in patients with drug-eluting stents. Catheterization and cardiovascular interventions : official journal of the Society for Cardiac Angiography & Interventions. Mar 1 2012;79(4):575-582.22448399
26 Eberli D, Chassot PG, Sulser T Urological surgery and antiplatelet drugs after cardiac and cerebrovascular accidents. The Journal of urology. Jun 2010;183(6):2128-2136.20399452
27 Albaladejo P, Marret E, Samama CM Non-cardiac surgery in patients with coronary stents: the RECO study. Heart (British Cardiac Society). Oct 2011;97(19):1566-1572.21791513
28 Dalal AR, D'Souza S, Shulman MS. Brief review: coronary drug-eluting stents and anesthesia. Canadian journal of anaesthesia = Journal canadien d'anesthesie. Dec 2006;53(12):1230-1243.
29 Albaladejo P, Charbonneau H, Samama CM Bleeding complications in patients with coronary stents during non-cardiac surgery. Thrombosis research. Aug 2014;134(2):268-272.24913999
30 Cruden NL, Harding SA, Flapan AD Previous coronary stent implantation and cardiac events in patients undergoing noncardiac surgery. Circulation. Cardiovascular interventions. Jun 1 2010;3(3):236-242.20442357
31 Fujikawa T, Tanaka A, Abe T, Yoshimoto Y, Tada S, Maekawa H. Effect of antiplatelet therapy on patients undergoing gastroenterological surgery: thromboembolic risks versus bleeding risks during its perioperative withdrawal. World journal of surgery. Jan 2015;39(1):139-149.25201469
32 Stone DH, Goodney PP, Schanzer A Clopidogrel is not associated with major bleeding complications during peripheral arterial surgery. Journal of vascular surgery. Sep 2011;54(3):779-784.21571492
33 Gandhi NK, Abdel-Karim AR, Banerjee S, Brilakis ES. Frequency and risk of noncardiac surgery after drug-eluting stent implantation. Catheterization and cardiovascular interventions : official journal of the Society for Cardiac Angiography & Interventions. Jun 1 2011;77(7):972-976.20824750
34 Said SM, Esperer HD, Hahn J Influence of oral antiplatelet therapy on hemorrhagic complications of pacemaker implantation. Clinical research in cardiology : official journal of the German Cardiac Society. May 2013;102(5):345-349.23386254
35 Finkel JB, Marhefka GD, Weitz HH. Dual antiplatelet therapy with aspirin and clopidogrel: what is the risk in noncardiac surgery? A narrative review. Hospital practice (1995). Feb 2013;41(1):79-88.23466970
36 Anwaruddin S, Askari AT, Saudye H Characterization of post-operative risk associated with prior drug-eluting stent use. JACC. Cardiovascular interventions. Jun 2009;2(6):542-549.19539259
37 Saadeh C, Sfeir J. Discontinuation of preoperative clopidogrel is unnecessary in peripheral arterial surgery. Journal of vascular surgery. Dec 2013;58(6):1586-1592.23891491
38 Mortezavi A, Hermanns T, Hefermehl LJ Continuous low-dose aspirin therapy in robotic-assisted laparoscopic radical prostatectomy does not increase risk of surgical hemorrhage. Journal of laparoendoscopic & advanced surgical techniques. Part A. Jun 2013;23(6):500-505.23611162
39 Paul S, Stock C, Chiu YL Management and outcomes of patients on preoperative plavix (clopidogrel) undergoing general thoracic surgery. The Thoracic and cardiovascular surgeon. Sep 2013;61(6):489-495.23165759
40 Abdel Samie AA, Sun R, Vohringer U, Theilmann L. Safety of endoscopic sphincterotomy in patients under dual antiplatelet therapy. Hepato-gastroenterology. Jun 2013;60(124):659-661.23187292
41 Chechik O, Goldstein Y, Behrbalk E, Kaufman E, Rabinovich Y. Blood loss and complications following carotid endarterectomy in patients treated with clopidogrel. Vascular. Aug 2012;20(4):193-197.22577162
42 Rahman M, Donnangelo LL, Neal D, Mogali K, Decker M, Ahmed MM. Effects of Perioperative Acetyl Salicylic Acid on Clinical Outcomes in Patients Undergoing Craniotomy for Brain Tumor. World neurosurgery. Jul 2015;84(1):41-47.25727304
43 Girotra C, Padhye M, Mandlik G Assessment of the risk of haemorrhage and its control following minor oral surgical procedures in patients on anti-platelet therapy: a prospective study. International journal of oral and maxillofacial surgery. Jan 2014;43(1):99-106.24074486
44 Alcock RF, Kouzios D, Naoum C, Hillis GS, Brieger DB. Perioperative myocardial necrosis in patients at high cardiovascular risk undergoing elective non-cardiac surgery. Heart (British Cardiac Society). May 2012;98(10):792-798.22543837
45 Antolovic D, Reissfelder C, Rakow A A randomised controlled trial to evaluate and optimize the use of antiplatelet agents in the perioperative management in patients undergoing general and abdominal surgery--the APAP trial (ISRCTN45810007). BMC surgery. 2011;11:7.21371292
46 Pigot F, Juguet F, Bouchard D, Castinel A. Do we have to stop anticoagulant and platelet-inhibitor treatments during proctological surgery? Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Dec 2012;14(12):1516-1520.22564791
47 Hollis RH, Graham LA, Richman JS, Deierhoi RJ, Hawn MT. Adverse cardiac events in patients with coronary stents undergoing noncardiac surgery: a systematic review. American journal of surgery. Oct 2012;204(4):494-501.22867724
48 Bertolaccini L, Terzi A, Rizzardi G Risk is not our business: safety of thoracic surgery in patients using antiplatelet therapy. Interactive cardiovascular and thoracic surgery. Feb 2012;14(2):162-166.22159230
49 Devereaux PJ, Mrkobrada M, Sessler DI Aspirin in patients undergoing noncardiac surgery. The New England journal of medicine.Apr 17 2014;370(16):1494-1503.24679062
50 Picozzi S, Marenghi C, Ricci C, Bozzini G, Casellato S, Carmignani L. Risks and complications of transurethral resection of bladder tumor among patients taking antiplatelet agents for cardiovascular disease. Surgical endoscopy. Jan 2014;28(1):116-121.24002913
51 Bogunovic L, Gelberman RH, Goldfarb CA, Boyer MI, Calfee RP. The impact of antiplatelet medication on hand and wrist surgery. The Journal of hand surgery. Jun 2013;38(6):1063-1070.23707007
52 Widimsky P, Motovska Z, Havluj L Perioperative cardiovascular complications versus perioperative bleeding in consecutive patients with known cardiac disease undergoing non-cardiac surgery. Focus on antithrombotic medication. The PRAGUE-14 registry. Netherlands heart journal : monthly journal of the Netherlands Society of Cardiology and the Netherlands Heart Foundation. Sep 2014;22(9):372-379.
53 Bangalore S, Silbaugh TS, Normand SL, Lovett AF, Welt FG, Resnic FS. Drug-eluting stents versus bare metal stents prior to noncardiac surgery. Catheterization and cardiovascular interventions : official journal of the Society for Cardiac Angiography & Interventions. Mar 2015;85(4):533-541.25059742
54 Kim HL, Park KW, Kwak JJ Stent-related cardiac events after non-cardiac surgery: drug-eluting stent vs bare metal stent. International journal of cardiology. Jan 24 2008;123(3):353-354.17346821
55 Berger PB, Kleiman NS, Pencina MJ Frequency of major noncardiac surgery and subsequent adverse events in the year after drug-eluting stent placement results from the EVENT (Evaluation of Drug-Eluting Stents and Ischemic Events) Registry. JACC. Cardiovascular interventions. Sep 2010;3(9):920-927.20850090
56 Brichon PY, Boitet P, Dujon A Perioperative in-stent thrombosis after lung resection performed within 3 months of coronary stenting. European journal of cardio-thoracic surgery : official journal of the European Association for Cardio-thoracic Surgery. Nov 2006;30(5):793-796.16996274
57 Chia KK, Park JJ, Postle J, Cottrill A, Ward MR. Frequency of late drug-eluting stent thrombosis with non-cardiac surgery. The American journal of cardiology. Jul 1 2010;106(1):1-3.20609638
58 Omar HR, Sprenker C, Karlnoski R, Camporesi EM, Mangar D. Late and very late drug-eluting stent thrombosis in the immediate postoperative period after antiplatelet withdrawal: a retrospective study. Therapeutic advances in cardiovascular disease. Oct 2014;8(5):185-192.25015068
59 Graham LA, Singletary BA, Richman JS, Maddox TM, Itani KM, Hawn MT. Improved adverse postoperative outcomes with revised American College of Cardiology/American Heart Association guidelines for patients with cardiac stents. JAMA surgery. Nov 2014;149(11):1113-1120.25188466
60 Saia F, Belotti LM, Guastaroba P Risk of Adverse Cardiac and Bleeding Events Following Cardiac and Noncardiac Surgery in Patients With Coronary Stent: How Important Is the Interplay Between Stent Type and Time From Stenting to Surgery? Circulation. Cardiovascular quality and outcomes. Dec 8 2015.
61 Jain R, Sood J. Antiplatelet therapy in patients with coronary artery stents for noncardiac surgery: Role of thromboelastography. Journal of anaesthesiology, clinical pharmacology. Oct 2011;27(4):537-540.
62 Piscione F, Cassese S, Galasso G A new approach to percutaneous coronary revascularization in patients requiring undeferrable non-cardiac surgery. International journal of cardiology. Feb 3 2011;146(3):399-403.19700208
63 Abdel Samie A, Stumpf M, Sun R, Theilmann L. Biliary-Pancreatic Endoscopic and Surgical Procedures in Patients under Dual Antiplatelet Therapy: A Single-Center Study. Clinical endoscopy. Jul 2013;46(4):395-398.23964338
64 Bolsin SN, Gillett J. Drug-eluting stents and noncardiac surgery. Chest. May 2014;145(5):1174.
65 Calderaro D, Marques AC, Yu PC, Gualandro DM, Caramelli B. Bare metal stenting and noncardiac surgery, how long should we wait? The American journal of cardiology. Apr 1 2010;105(7):1040-1041; author reply 1041-1042.
66 Udroiu C. More then 12 months of dual antiplatelet therapy after implantation of drug-eluting stents? Maedica. Jan 2010;5(1):73-74.21977126
67 Chen G, A J B. Perioperative management of antithrombotic medications in vitreoretinal surgery. International Ophthalmology Clinics. 2014;54(2):199-213.24613893
68 Spyropoulos AC, Albaladejo P, Godier A Periprocedural antiplatelet therapy: recommendations for standardized reporting in patients on antiplatelet therapy: communication from the SSC of the ISTH. Journal of Thrombosis and Haemostasis. Aug 2013;11(8):1593-1596.23647986
69 Liu ZJ, Yu CH, Xu L, Han W, Jiang JM, Huang YG. Risk factors for perioperative major cardiac events in Chinese elderly patients with coronary heart disease undergoing noncardiac surgery. Chinese medical journal. Sep 2013;126(18):3464-3469.24034091
70 Tokushige A, Shiomi H, Morimoto T Influence of initial acute myocardial infarction presentation on the outcome of surgical procedures after coronary stent implantation: A report from the CREDO-Kyoto PCI/CABG Registry Cohort-2. Cardiovascular intervention and therapeutics. 2013;28(1):45-55.23015155
71 DeVile MPJ, Foëx P. Antiplatelet drugs, coronary stents, and non-cardiac surgery. Continuing Education in Anaesthesia, Critical Care and Pain. 2010;10(6):187-191.
72 Vetter TR, Short RT, Hawn MT, Marques MB. Perioperative Management of the Patient with a Coronary Artery Stent. Anesthesiology. Nov 2014;121(5):1093-1098.25211171
73 Fernandez FG, Crabtree TD, Liu JX, Meyers BF. Incremental Risk of Prior Coronary Arterial Stents for Pulmonary Resection. Annals of Thoracic Surgery. Apr 2013;95(4):1212-1220.23465849
74 Nikolsky E, Beyar R. Drug-Eluting Stents and Non-Cardiac Surgery: Learning Lessons the Hard Way. Journal of Invasive Cardiology. Jul 2011;23(7):287-289.21725124
75 Brilakis ES, Cohen DJ, Kleiman NS Incidence and clinical outcome of minor surgery in the year after drug-eluting stent implantation: Results from the Evaluation of Drug-Eluting Stents and Ischemic Events Registry. American heart journal. Feb 2011;161(2):360-366.21315220
76 Alshawabkeh LI, Banerjee S, Brilakis ES. Systematic Review of the Frequency and Outcomes of Non-Cardiac Surgery After Drug-Eluting Stent Implantation. Hellenic Journal of Cardiology. Mar-Apr 2011;52(2):141-148.21478124
77 Savonitto S, De Servi S. Tirofiban ‘bridging’ therapy for patients with drug-eluting stents undergoing non-cardiac surgery - Conflict of interest. British journal of anaesthesia. Jun 2010;104(6):779-780.20460570
78 Brancati MF, Giammarinaro M, Burzotta F Outcome of non-cardiac surgery after stent implantation in the DES era: results of the Surgery After Stent (SAS) registry. The Journal of invasive cardiology. Feb 2011;23(2):44-49.21297198
79 D'Ascenzo F, Bollati M, Clementi F Incidence and predictors of coronary stent thrombosis: evidence from an international collaborative meta-analysis including 30 studies, 221,066 patients, and 4276 thromboses. International journal of cardiology. Jul 31 2013;167(2):575-584.22360945
80 Rhee SJ, Yun KH, Lee SR Drug-eluting stent thrombosis during perioperative period. International heart journal. Mar 2008;49(2):135-142.18475013
81 Godet G, Le Manach Y, Lesache F, Perbet S, Coriat P. Drug-eluting stent thrombosis in patients undergoing non-cardiac surgery: is it always a problem? British journal of anaesthesia. Apr 2008;100(4):472-477.18310674
82 Schouten O, van Domburg RT, Bax JJ Noncardiac surgery after coronary stenting: early surgery and interruption of antiplatelet therapy are associated with an increase in major adverse cardiac events. Journal of the American College of Cardiology. Jan 2 2007;49(1):122-124.17207733
83 Compton PA, Zankar AA, Adesanya AO, Banerjee S, Brilakis ES. Risk of noncardiac surgery after coronary drug-eluting stent implantation. The American journal of cardiology. Nov 1 2006;98(9):1212-1213.17056330
84 Reddy PR, Vaitkus PT. Risks of noncardiac surgery after coronary stenting. The American journal of cardiology. Mar 15 2005;95(6):755-757.15757604
85 Sharma AK, Ajani AE, Hamwi SM Major noncardiac surgery following coronary stenting: when is it safe to operate? Catheterization and cardiovascular interventions : official journal of the Society for Cardiac Angiography & Interventions. Oct 2004;63(2):141-145.15390248
86 Brancati MF, Giammarinaro M, Burzotta F Outcome of non-cardiac surgery after stent implantation in the DES era: results of the Surgery After Stent (SAS) registry. The Journal of invasive cardiology. 2011;23(2):44-49.21297198