# APPENDIX B PEER REVIEW COMMENTS/AUTHOR RESPONSES

Comments | Response
p 6; line 15: typo - these | This has been corrected.
p 7; line 13; dual antiplatelet therapy might be better defined as “(aspirin plus a P2Y12 inhibitor)” rather than (almost always clopidogrel and aspirin). Historically, clopidogrel and aspirin has been prescribed. But, use of newer agents such as ticagrelor (and prasugrel) are increasing. | This has now been corrected to “aspirin plus a P2Y12 inhibitor.)” We also elected to add your additional clarification. “Historically, clopidogrel and aspirin has been prescribed. But, use of newer agents such as ticagrelor and prasugrel are increasing.”
p. 22; key question 4: I would suggest mentioning whether any of the newer antiplatelet agents were included (or state that only clopidogrel was studied). The differentiation is noteworthy because theoretically there may be a concern of more bleeding with ticagrelor/prasugrel since they are more potent antiplatelet agents than clopidogrel. | Yes, we included any of the P2Y12 agents, which we clarified on page 4, paragraph 3;. and page 9, paragraph 1. “We did not exclude studies based on the type of APT management (ie, all P2Y12 agents were eligible).” Of note, the majority of the included studies looked at clopidogrel.
p. 24; Is the evidence strong enough to conclude that the heterogeneity observed suggests factors other than periop management of antiplatelet therapy are responsible for differences? Or, have no differences been detected because no clinical trials have been conducted adequately assessing for outcomes differences? Would “may” be a better description rather than “suggests”? It would also be helpful to provide some examples of other factors that may influence bleeding/MACE in this population and whether the examples are supported by evidence. | We agree with your comments and have changed the conclusions (page 6, last paragraph; and page 22, first paragraph). “This heterogeneity, combined with small sample sizes, limited the ability to assess the impact of the different aspects of APT – timing of cessation, bridging, restarting therapy, and type of APT. Additionally, the varied range of invasiveness of the procedure, skin excisions to major thoracic cases, contributes to the operative bleeding risk and MACE risk, yet many studies lacks sufficient detail to assess the impact of procedure on the outcomes. These results also suggest that clinical factors other than perioperative APT may be in part responsible for differences in bleeding and MACE rates observed between studies.” Similar edits were made for page 5, last paragraph. “The heterogeneity observed limited the ability to adequately assess the impact of APT management for the wide range of procedures. It is likely that factors other than perioperative management of APT play a role in differences in bleeding and MACE rates observed between studies.” We also provided to the discussion more comments about possible other reasons for developing MACE or bleeding events and added these sentences to our discussion (page 23, paragraph 2). “We theorize that several factors make work in conjunction and be associated with bleeding and MACE events, but the data were too limited to help address this. For example, it is likely that the type of APT and the invasiveness of the operation combined may be associated with bleeding and MACE. However, the majority of studies included a wide range of procedures (skin excision through to thoracic surgery) and the APT management also varied between studies (timing, dual versus single preoperative, cessation versus continuing, and use of bridging). Additionally, the outcomes and APT management were often only reported for cases where an event occurred, thus the management of those without an event was unknown. This prevented us from identifying whether one APT management, for a particular type of procedure or group of procedures was protective or harmful. Another possibility is that whether or not the patients' cardiac status was optimized or if they were satisfactorily cleared from a cardiac standpoint was absent from the studies. For example, we could not assess the adequacy of their level of beta blockade, functional status, or cardiac function at the time of surgery. Additionally, perioperative management can also impact development of MACE, such as fluid management, which was not reported in the studies.”
Appendix C | We made some cosmetic edits to this appendix to help improve the presentation of the data.