# APPENDIX A SEARCH STRATEGIES

## ANTIPLATELET THERAPY – SEARCH METHODOLOGY

Database Searched and Time Period Covered:

PubMed – From inception to 12/17/2015

Language:

English

Search Strategy:

“Platelet Aggregation Inhibitors”[Mesh] OR antiplatelet therap* OR anti-platelet therap*

AND

pci OR percutaneous coronary intervention*

NOT

stop OR stopped OR stopping OR discontinu*

____________________________________________________________________

Database Searched and Time Period Covered:

PubMed – From inception to 12/17/2015

Language:

English

Search Strategy:

“Similar Article” searches on the following articles:

van Kuijk, J.P., W. J. Flu (2009). “Timing of noncardiac surgery after coronary artery stenting with bare metal or drug-eluting stents.” Am J Cardiol 104(9): 1229-1234 19840567 .

Sandeep Singla, Sandeep, Rajesh Sachdeva, , Barry F. Uretsky, (2012). “The Risk of Adverse Cardiac and Bleeding Events Following Noncardiac Surgery Relative to Antiplatelet herapy in Patients With Prior Percutaneous Coronary Intervention.” Journal of the American College of Cardiology Vol. 60, No. 20, 2005-16 23083781 .

Albaladejo, P., E. Marret (2011). “Non-cardiac surgery in patients with coronary stents: the RECO study.” Heart 97(19): 1566-1572 21791513 .

____________________________________________________________________

Databases Searched and Time Period Covered:

Web of Science and Scopus – From inception to 12/17/2015

Language:

English

Search Strategy:

“Forward (Citation)” searches on the 3 articles cited above.