# ABBREVIATIONS TABLE

PCI: percutaneous coronary intervention
TEP: technical expert panel
MACE: major adverse cardiac events
APT: antiplatelet therapy
DAPT: dual antiplatelet therapy
SAPT: single antiplatelet therapy