# SUMMARY AND DISCUSSION

## SUMMARY OF RESULTS BY KEY QUESTION

### Key Question 1 What is the effectiveness of antimicrobial stewardship programs in outpatient settings on the following

a. Primary Outcome: Antimicrobial prescribing (decision to prescribe, selection of antimicrobial, duration of treatment, guideline concordant use)
b. Secondary Outcomes:
  1. Patient centered outcomes (return clinic visits, hospital admission, adverse events, late antimicrobial prescription, patient satisfaction with care);
  2. Microbial outcomes (resistance in study population);
  3. Costs (program costs, drug costs)?

#### Existing Systematic Review

An existing systematic review and 2 publications based on the review included studies of quality improvement strategies (ie, clinician education, patient education, education combined with audit and feedback, etc) to improve antimicrobial prescribing.13 For interventions aimed at reducing unnecessary prescribing, the median reduction in the proportion of subjects receiving antimicrobials was 9.7% (median follow-up of 6 months). The interventions were largely educational and directed toward clinicians and/or patients. There was no clear advantage to any of the interventions. For interventions aimed at improving antimicrobial selection the median improvement in recommended prescribing was 10.6%. Although clinician education with audit and feedback was less effective than clinician education alone, potential confounders were identified. Overall, the quality improvement interventions did not adversely impact patient outcomes.

#### Updated Evidence Newly Identified for this Evidence Report

We identified 50 trials meeting eligibility criteria that were not included in the systematic review. There were 17 RCTs, 18 CRCTs, 3 CCTs, 6 CBA studies, and 6 ITS studies. Sixteen trials focused on provider and/or patient education, 5 on provider feedback, 6 on guideline implementation, 4 on delayed prescribing, 6 on communication skills training, 2 on formulary restriction, 6 on decision support, one on financial incentives, and 9 on laboratory testing (ie, rapid antigen testing, PCR, and C-reactive protein). Two studies included data from VA Health Care Systems. Prescribing, patient, and cost outcomes were reported; none of the studies reported microbial outcomes.

Provider and/or patient education, guideline implementation, delayed prescribing, communication skills training, decision support, and laboratory testing interventions (rapid antigen testing, a PCR assay, and C-reactive protein testing) were generally associated with significant reductions in antimicrobial use (Table 13). Results were less conclusive for provider feedback, formulary restriction, and financial incentives due to either mixed results across studies or few studies of the intervention type. Few interventions provided sufficient information to reach conclusions about antimicrobial selection. Similarly, there was limited reporting for the outcomes duration of therapy and guideline concordant use of antimicrobials.

Table 13 Strength of Evidence for Outpatient Antimicrobial Stewardship Studies, Antimicrobial Prescribing

Study, year | Study design | Purpose of intervention | Risk of bias | Outcome | Finding versus control or prior to implementation (or as noted) | Strength of evidence, by outcome
A. Provider and/or Patient Education Studies (k=16)
Gerber 2012^20^ | CRCT | Reduce inappropriate antimicrobials for pediatric acute RTIs | Medium | Proportion of broad-spectrum antimicrobials | Intervention: 12.5% decrease Control: 5.8% decrease Treatment by time interaction: p=0.01 | Low For Antimicrobial Prescribing
Vinnard 2013^21^ | CBA | Reduce antimicrobials for upper respiratory infection | High | Antimicrobial use | Intervention: 4.7% decrease Control: 1.2% increase; p=0.133 | Low For Antimicrobial Prescribing
Butler 2012^22^ | RCT | Reduce antimicrobials for all causes | Medium | Oral antimicrobial dispensing | % reduction: 4.9 [95% CI 0.5, 7.7]; p=0.02 | Low For Antimicrobial Prescribing
Llor 2012^23,24^ | CBA | Reduce antimicrobials for lower RTIs | Medium | Antimicrobial prescription rate | LRTI: OR 0.42 [95% CI 0.22, 0.82]; p=0.01^*^ | Low For Antimicrobial Prescribing
Regev-Yochay 2011^25^ | CRCT | Reduce prescription rates (pediatric) | High | Antimicrobial prescription rate | RR 0.76 [95% CI 0.75, 0.78] | Low For Antimicrobial Prescribing
Esmaily 2010^26^ | CRCT | Decrease use of antimicrobials | High | % of prescriptions with antimicrobial | NS | Low For Antimicrobial Prescribing
Smeets 2009^27^ | CBA | Reduce antimicrobials for acute RTIs | High | Number of antimicrobial prescriptions | NS | Low For Antimicrobial Prescribing
Finkelstein 2008^28^ | CRCT | Reduce unnecessary antimicrobial use (pediatric) | Medium | Adjusted % change in prescribing | Change between intervention and control communities Age 3 to <24 mos: -0.5%; p=0.69 Age 24 to <48 mos: -4.2%; p<0.01 Age 48 to <72 mos: -6.7%; p<0.0001 | Low For Antimicrobial Prescribing
Chazan 2007^29^ | RCT | Increase appropriate use of antimicrobials | High | Total antimicrobial use | Continuous intervention group: 20.0% reduction Seasonal intervention group: 16.5% reduction p<0.0001 | Low For Antimicrobial Prescribing
Metlay 2007^30^ | CRCT | Reduce antimicrobial use for acute RTIs in the emergency department | Medium | Antimicrobials for URTIs and acute bronchitis | Adjusted differences (intervention year – baseline year) Intervention sites: -10% [95% CI -18%, -2%] Control sites: 0.5% [95% CI -3%, 5%] | Low For Antimicrobial Prescribing
van Driel 2007^31^ | CRCT | Increase rational use of antimicrobials for acute rhinosinusitis | High | Antimicrobial prescriptions | OR_adj_ 0.63 [95% CI 0.29, 1.37] | Low For Antimicrobial Prescribing
Little 2005^33^ | RCT | Effectiveness of 3 prescribing strategies and an information leaflet (see delayed prescribing) | Medium | Self-reported use of antimicrobials | Leaflet: 55% No leaflet: 57%; p=0.58^†^ | Low For Antimicrobial Prescribing
Pagaiya 2005^34^ | RCT | Improve quality of care | Medium | Antimicrobial prescribing | ARTI Intervention: mean change -14.6% Control: mean change 2.8%; p=0.022 Diarrhea Intervention: mean change -1.8% Control: mean change -2.1%; p=0.308 | Low For Antimicrobial Prescribing
Gonzales 2004^35^ | CCT | Improve antimicrobial use for acute RTIs (elderly) | High | Prescription rate for ARTIs | NS | Low For Antimicrobial Prescribing
Stewart 2000^36^ | CBA | Improve antimicrobial use | High | Total antimicrobial claims | Analysis of before and after data: 9.4% decrease in claims; p=NR | Low For Antimicrobial Prescribing
B. Provider Feedback (k=5)
Gjelstad 2013^37^ | CRCT | Reduce antimicrobial prescribing for acute RTIs and reduce use of broad-spectrum antimicrobials | High | ARTI episodes with antimicrobial prescription | OR 0.72 [95% CI 0.61, 0.84] | Low For Antimicrobial Prescribing
Vinnard 2013^21^ | CBA | Reduce antimicrobial prescribing for URTIs | High | Antimicrobial prescribing | Change in prescribing relative to control Intensive intervention: ROR 2.60 [95% CI 1.23, 5.45] Mild intervention: ROR 1.67 [95% CI 0.74, 3.79] | Low For Antimicrobial Prescribing
Linder 2010^38^ | CRCT | Reduce inappropriate prescribing for acute respiratory infections | High | Oral antimicrobial within 3 days of ARI visit | OR 0.97 [95% CI 0.7, 1.4]; p=0.87 | Low For Antimicrobial Prescribing
Naughton 2009^39^ | RCT | Reduce overall antimicrobial prescribing and 2^nd^-line prescribing | High | Antimicrobial prescribing | NS | Low For Antimicrobial Prescribing
Madridejos 2004^40^ | CCT | Improve quality of prescribing | Medium | Over prescription of antimicrobials | Change in intervention group pre to post intervention: p=0.006 Difference between intervention and control groups post-intervention: p=0.026 | Low For Antimicrobial Prescribing
C. Guidelines (k=6)
Venekamp 2012^43^ | ITS | Change prescription rates for acute rhinosinusitis | Medium | Prescription rate | Post-intervention slope significantly different from pre-intervention slope (p<0.05) | Low For Antimicrobial Prescribing
Weiss 2011^44^ | ITS | Effect of guidelines on antimicrobial use | Medium | Difference in prescribing | Significant level change after guideline dissemination (p=0.002) | Low For Antimicrobial Prescribing
Seager 2006^45^ | CRCT | Assess effect of education outreach visits on prescribing for dental pain | Medium | Odds of prescription; odds of inappropriate prescription | Prescription: OR 0.63 [95% CI 0.41, 0.95]; p<0.05 Inappropriate prescription: OR 0.33 [95% CI 0.21, 0.54]; p<0.05 | Low For Antimicrobial Prescribing
Martens 2006^46^ | CCT | Effect of guidelines on volume of prescriptions | High | Total antimicrobial prescriptions per GP per year | NS | Low For Antimicrobial Prescribing
D. Delayed Prescribing (k=4)
Cals 2010^71^ | RCT | Effect on management of lower RTI and rhinosinusitis | Medium | Filled delayed prescription | Intervention 23%, Control 72%; p<0.001 | Low For Antimicrobial Prescribing
Little 2010^47^ | RCT | Effect of management strategies for UTI | Medium | Antimicrobial use | Delayed group vs control: OR 0.12 [95% CI 0.03, 0.59] | Low For Antimicrobial Prescribing
Worrall 2010^48^ | RCT | Reduce antimicrobial use for ARTIs | High | Prescriptions filled | Usual date 43%, Post date 44%, p=0.924 | Low For Antimicrobial Prescribing
Little 2005^33^ | RCT | Effectiveness of 3 prescribing strategies and an information leaflet (see education) | Medium | Self-reported use of antimicrobials | No antimicrobials 16%, delayed 20%, immediate 96%; p<0.001 | Low For Antimicrobial Prescribing
E. Communication Skills Training (k=6)
Little 2013^49^ | CRCT | Effects of internet-based training on antimicrobial prescribing for lower and upper RTIs | Medium | Antimicrobial use | Communication training vs no communication training: RR_adj_ 0.69 [95% CI 0.53, 0.87]; p<0.0001 | MEDIUM For Antimicrobial Prescribing
Légaré 2012^50^ | CRCT | Reduce overuse of antimicrobials for acute RTIs | Medium | Patient decision to use antimicrobials after consultation | RR_adj_ 0.50 [95% CI 0.3, 0.7] | MEDIUM For Antimicrobial Prescribing
Légaré 2010^51^ | CRCT | Reduce overuse of antimicrobials for acute RTIs | Medium | Patient decision to use antimicrobials after consultation | Absolute difference 16% [95% CI -31, 1]; p=0.08 | MEDIUM For Antimicrobial Prescribing
Cals 2009^52^ | CRCT | Effect of skills training on prescribing | High | Antimicrobials at index consultation | Communication training 27%, no training 54%; p<0.01 | MEDIUM For Antimicrobial Prescribing
Francis 2009^55^ | CRCT | Reduce use and return clinic visit (pediatric) | Medium | Antimicrobials at index consultation | OR 0.29 [95% CI 0.14, 0.60] | MEDIUM For Antimicrobial Prescribing
Altiner 2007^56^ | CRCT | Reduce unnecessary antimicrobial prescribing for acute cough | High | Antimicrobials prescribed | At 6-weeks post-intervention OR_adj_ 0.38 [95% CI 0.26, 0.56]; p<0.001 | MEDIUM For Antimicrobial Prescribing
F. Formulary Restriction (k=2)
Manns 2012^57^ | ITS | Restrict quinolone use | Medium | Quinolone use | NS (level and slope) | Low For Antimicrobial Prescribing
Marshall 2006^58^ | ITS | Restrict fluoroquinolone reimbursement | Low | Prescriptions per week for fluoroquinolone group (3 of 6 antimicrobials restricted) | p<0.0001 for level NS for trend | Low For Antimicrobial Prescribing
G. Decision Support (k=6)
Gonzales 2013^59^ | CRCT | Reduce use of antimicrobials for acute bronchitis | High | Antimicrobial prescriptions | Intervention period vs baseline Printed decision support: OR_adj_ 0.57 [95% CI 0.40, 0.82] Computer-assisted decision support: OR_adj_ 0.64 [95% CI 0.45, 0.91] Usual care: NS | Low For Antimicrobial Prescribing
Jenkins 2013^60^ | RCT | Decrease prescribing for non-pneumonia acute respiratory infection | Medium | Antimicrobials for ARIs | Significant time trend (p<0.0001); significant difference in trend between intervention and control (p<0.0001) | Low For Antimicrobial Prescribing
McGinn 2013^61^ | RCT | Effect on management of respiratory tract infections | High | Antimicrobial prescriptions | ARD 0.82, RR_adj_ 0.74 [95% CI 0.60, 0.92]; p=0.008 | Low For Antimicrobial Prescribing
Rattinger 2012^62^ | CBA | Minimize unnecessary use of antimicrobials | High | Proportion of unwarranted prescriptions | Intervention period vs baseline Targeted antimicrobials; p<0.0001 at intervention sites, p=ns at control sites | Low For Antimicrobial Prescribing
Linder 2009^63^ | CRCT | Reduce inappropriate prescribing | High | Prescriptions to patients with ARI diagnosis | OR 0.80 [95% CI 0.6, 1.2]; p=0.30 | Low For Antimicrobial Prescribing
Martens 2007^64^ | CRCT | Change prescribing behavior | High | Prescriptions | NS | Low For Antimicrobial Prescribing
H. Financial Incentive (k=1)
Martens 2007^65^ | CBA | Reduce volume of prescriptions and improve quality of prescribing | High | Prescriptions | NS for Quinolones, nitrofurantoin, amoxicillin, mupriocin p<0.05 for trimethoprim, amoxicillin + clavulanic acid, doxycycline | Low For Antimicrobial Prescribing
I. Procalcitonin, Rapid Antigen Detection Tests, Polymerase Chain Reaction Assay, and C-Reactive Protein (k=9)
Little 2013^66^ | RCT | Effect of rapid streptococcal antigen detection test on prescribing for sore throat | High | Antibiotic use | Compared to delayed prescribing (control) Clinical score + RADT RR 0.73 [95% CI 0.52, 0.98]; p=0.03 Clinical score: RR0.71 [95% CI 0.50, 0.95]; p=0.02 | MEDIUM For Antimicrobial Prescribing
Brittain-Long 2011^67^ | RCT | Effect of rapid test for respiratory virus | Medium | Prescriptions (early result vs late result) | Early: 4.5% Late: 12.3%; p=0.005 | MEDIUM For Antimicrobial Prescribing
Worrall 2007^68^ | RCT | Compared clinical judgment, rapid antigen detection test, and decision rules for patients with sore throat | High | Prescriptions | p<0.001 for rapid antigen test vs usual care | MEDIUM For Antimicrobial Prescribing
Diederischsen 2000^69^ | RCT | Effect of CRP testing on prescribing for RTI | Medium | Prescriptions | OR 0.90 [95% CI 0.7, 1.2] | MEDIUM For Antimicrobial Prescribing
Takemura 2005^70^ | RCT | Effect of immediate availability of WBC and CRP results on prescribing for any infection | High | Prescriptions | CRP+WBC: 52% Usual care: 88%; p<0.001 | MEDIUM For Antimicrobial Prescribing
Cals 2009^52^ | CRCT | Effect of CRP and communication skills training for lower RTI | High | Prescriptions | CRP: 31% No CRP: 53%; p=0.02 | MEDIUM For Antimicrobial Prescribing
Cals 2010^71^ | RCT | Effect of CRP testing on prescribing for lower RTI and rhinosinusitis | Medium | Prescriptions | CRP vs No CRP: RR 0.77 [95% CI 0.56, 0.98] | MEDIUM For Antimicrobial Prescribing
Llor 2012^23,24^ | CBA | Effect of CRP testing on prescribing for lower RTI or acute rhinosinusitis | Medium | Prescriptions | Full intervention vs usual care LRTI: OR 0.22 [95% CI 0.12, 0.38]; p=0.00 ARS: OR 0.12 [95% CI 0.01, 0.32]; p=0.01 | MEDIUM For Antimicrobial Prescribing
Little 2013^49^ | CRCT | Effects of internet-based training for CRP for patients with lower or upper RTI | Medium | Prescriptions | CRP training vs no CRP training RR_adj_ 0.54 [95% CI 0.42, 0.69]; p<0.0001 | MEDIUM For Antimicrobial Prescribing

RCT = randomized controlled trial; CRCT = cluster randomized controlled trial; ITS = interrupted time series; CCT = controlled clinical trial; CBA = controlled before and after study; RTI = respiratory tract infection; UTI = urinary tract infection; RADT = rapid antigen detection test; CRP = C-reactive protein; WBC = white blood cell count; NS = not statistically significant; OR = odds ratio [95% confidence interval]; RR = rate ratio [95% confidence interval]; IRR = incidence rate ratio [95% confidence interval]; HR = hazard ratio [95% confidence interval]; WMD = weighted mean difference; ROR = ratio of odds ratios

* Partial intervention (education without CRP) vs usual care; see Laboratory Test section for full intervention results (including CRP test)

† Education component only (see delayed prescribing)

For patient outcomes, where reported, there were few differences between intervention and control or from pre- to post-intervention in return clinic visits, hospitalizations, adverse events, late antimicrobial prescribing, or patient satisfaction (Table 14). Few studies reported cost data but in those that did, interventions were typically associated with lower drug costs.

Table 14 Strength of Evidence for Outpatient Antimicrobial Stewardship Studies, by Patient Outcome

Study, year | Study design | Purpose of intervention | Risk of bias | Outcome | Finding versus control or prior to implementation | Strength of evidence, by outcome
A. Provider and/or Patient Education Studies (k=14)
Butler 2012^22^ | RCT | Reduce antimicrobial dispensing for all causes | Medium | Return clinic visit | Within 31 days (intervention – control): -2.32 [95% CI -4.76, 1.95]; p=0.50 | Low for Return Clinic Visits
Metlay 2007^30^ | CRCT | Reduce antimicrobial overuse for ARTIs in the emergency department | Medium | Return clinic visit | Within 2 weeks: site by time interaction p=0.48 | Low for Return Clinic Visits
Little 2005^33^ | RCT | Effectiveness of 3 prescribing strategies and an information leaflet | Medium | Return clinic visit | Within 1 month (patient leaflet vs no leaflet): IRR 1.63 [95% CI 1.07, 2.49]; p=0.02 | Low for Return Clinic Visits
Butler 2012^22^ | RCT | Reduce antimicrobial dispensing for all causes | Medium | Hospitalization | % reduction (intervention relative to control): -1.9 [95% CI -13.2, 8.2]; p=0.72 | Low for Hospitalizations
Metlay 2007^30^ | CRCT | Reduce antimicrobial overuse for ARTIs in the emergency department | Medium | Hospitalization | Within 2 weeks: site by time interaction p=0.51 | Low for Hospitalizations
D. Delayed Prescribing (k=2)
Little 2010^47^ | RCT | Effectiveness of management strategies for women with urinary tract infection | Medium | Return clinic visit | Within 1 month (delayed prescribing vs control [immediate prescribing]): OR 0.44 [95% CI 0.21, 0.95] | Low for Return Clinic Visits
E. Communication Skills Training (k=6)
Légaré 2012^50^ | CRCT | Reduce overuse of antimicrobials for acute RTIs | Medium | Return clinic visit | RR 1.3 [95% CI 0.7, 2.3] | Low for Return Clinic Visits
Cals 2009^52^ | CRCT | Effect of skills training on prescribing | High | Return clinic visit | NS | Low for Return Clinic Visits
Francis 2009^55^ | CRCT | Reduce return clinic visit and antimicrobial use | Medium | Return clinic visit | Within 2 weeks (intervention vs control): OR 0.75 [95% CI 0.41, 1.38] | Low for Return Clinic Visits
Little 2013^49^ | CRCT | Effect of internet-based training on prescribing for LRTI and URTI | Medium | Hospitalization | NR (2 patients in usual care group, 6 patients in enhanced communication group) | Low for Hospitalizations
Cals 2009^52^ | CRCT | Effect of skills training on prescribing | High | Hospitalization | NS (no hospitalizations reported) | Low for Hospitalizations
F. Formulary Restriction (k=2)
Manns 2012^57^ | ITS | Effect of policy restricting quinolone use | Medium | Return clinic visit | Within 30 days: 55.6% before restriction, 56.5% after restriction (p<0.001) (NOTE: overall n=170,247) | Low for Return Clinic Visits
Manns 2012^57^ | ITS | Effect of policy restricting quinolone use | Medium | Hospitalization | All-cause: 4.9% before restriction, 5.2% after restriction (p=0.0001) | Low for Hospitalizations
G. Decision Support (k=6)
Gonzales 2013^59^ | CRCT | Reduce use of antimicrobials for acute bronchitis | High | Return clinic visit | NS | Low for Return Clinic Visits
Jenkins 2013^60^ | RCT | Decrease prescribing for non-pneumonia ARI | Medium | Return clinic visit | 8 to 30 days after initial visit: significant increase for control sites (p=0.02); non-significant decrease for intervention sites | Low for Return Clinic Visits
McGinn 2013^61^ | RCT | Effect on management of respiratory tract infections | High | Return clinic visit | Within 2 weeks: NS | Low for Return Clinic Visits
Linder 2009^63^ | CRCT | Reduce inappropriate prescribing | High | Return clinic visit | Within 30 days: 23% intervention 26% control; p=0.32 | Low for Return Clinic Visits
Gonzales 2013^59^ | CRCT | Reduce use of antimicrobials for acute bronchitis | High | Hospitalization | NS | Low for Hospitalizations
Jenkins 2013^60^ | RCT | Decrease prescribing for non-pneumonia ARI | Medium | Hospitalization | NS | Low for Hospitalizations
I. Procalcitonin, Rapid Antigen Detection Tests, Polymerase Chain Reaction Assay, and C-Reactive Protein (k=9)
Little 2013^66^ | RCT | Effect of rapid streptococcal antigen detection test on prescribing for sore throat | High | Return clinic visit | Within 1 month with sore throat (compared to delayed prescribing control) Clinical score + RADT RR 0.74 [95% CI 0.36, 1.47]; p=0.40 Clinical score: RR 0.91 [95% CI 0.47, 1.72]; p=0.78 | Low for Return Clinic Visits
Diederischsen 2000^69^ | RCT | Effect of CRP testing on prescribing for RTI | Medium | Return clinic visit | No differences in contact with health service | Low for Return Clinic Visits
Takemura 2005^70^ | RCT | Effect of WBC and CRP results on prescribing for ARTI | High | Return clinic visit | 30% intervention, 23% control; p=0.20 | Low for Return Clinic Visits
Cals 2009^52^ | CRCT | Effect of CRP and communication skills training for lower RTI | High | Return clinic visit | 35% CRP, 30% no CRP; p=ns | Low for Return Clinic Visits
Cals 2010^71^ | RCT | Effect of CRP testing on prescribing for lower RTI and rhinosinusitis | Medium | Return clinic visit | 26% CRP, 18% Usual care; p=ns | Low for Return Clinic Visits
Takemura 2005^70^ | RCT | Effect of WBC and CRP results on prescribing for ARTI | High | Hospitalization | 0.7% intervention, 0% control; p=ns | Low for Hospitalizations
Cals 2009^52^ | CRCT | Effect of CRP and communication skills training for lower RTI | High | Hospitalization | NS (no hospitalizations reported) | Low for Hospitalizations
Cals 2010^71^ | RCT | Effect of CRP testing on prescribing for lower RTI and rhinosinusitis | Medium | Hospitalization | NS (no hospitalizations reported) | Low for Hospitalizations
Little 2013^49^ | CRCT | Effects of internet-based training for CRP for patients with lower or upper RT | Medium | Hospitalization | CRP group vs no CRP group: OR 2.92 [95% CI 0.96, 8.85]; p=0.06 | Low for Hospitalizations

RCT = randomized controlled trial; CRCT = cluster randomized controlled trial ITS = interrupted time series; CCT = controlled clinical trial; CBA = controlled before and after study; ARI = acute respiratory infection; ARTI = acute respiratory tract infection; LRTI = lower respiratory tract infection; URTI = upper respiratory tract infection; CRP = C-reactive protein; WBC = white blood cell; NS = not statistically significant; OR = odds ratio [95% confidence interval]; RR = rate ratio [95% confidence interval]; IRR = incidence rate ratio [95% confidence interval]; HR = hazard ratio [95% confidence interval]; WMD = weighted mean difference

### Key Question 2 What are the key intervention components associated with effective outpatient antimicrobial stewardship (eg, type of intervention; personnel mix; level of support)?

Consistent findings across studies that surveyed intervention participants or speculated on effective components were the importance of leadership (ideally with peers as local champions, instructors, and/or discussion leaders) and use of a team approach (with input from health care professionals at all levels), patient education materials (ideally linked with provider materials on the same topic), provider reminders, user-friendly interfaces, and evidence-based materials.

### Key Question 3 Does effectiveness vary by a) clinic type or setting (primary care clinic vs emergency department or urgent care; VA, non-VA) or b) suspected patient condition (respiratory tract infections, urinary tract infections, soft-tissue infections)?

The majority of studies included in this review were conducted in primary care settings (including general practice, family practice, and pediatric clinics). The exceptions were studies in dental clinics, sexually transmitted disease clinics, emergency departments, and outpatient infectious disease clinics. It is impossible to comment on the effectiveness of interventions in sites other than primary care.

Similarly, respiratory infections were most commonly studied (29 of 50 trials). We also identified one study of patients with acute dental pain, 2 studies in patients with urinary tract infections, and one study of patients with sexually transmitted infections. The remaining studies did not specify an infection site. With so few studies of any infection other than respiratory, it is impossible to determine whether the effectiveness of interventions varies by infection site.

Two studies included patients from VA Medical Centers. Both reported improved prescribing outcomes. One study reported no difference in patient outcomes.

### Key Question 4 What are the harms of antimicrobial stewardship programs in outpatient settings?

None of the recent studies eligible for inclusion in the review reported possible harms of implementing ASPs in outpatient settings. There was only limited reporting of return clinic visits, hospitalizations, and adverse events (including mortality), with studies generally finding no significant differences between intervention and control groups.

### Key Question 5 Within the included studies, what are the barriers to implementation, sustainability, and scalability of antimicrobial stewardship programs in outpatient settings?

#### Implementation Facilitators

Familiar and simple applications were recommended for computer-based interventions. For education sessions, providers commented on location, scheduling, type of education, content, relevance, and focus of the training.

#### Scalability

Although most studies were conducted at multiple centers, little information was provided about implementation of interventions across centers. Three studies provided some insight. In one study, providers expressed concerns about how materials from one country would apply to their practice, specifically in consultation style, length of consultations sessions, nature of the patient/provider communication, fee structure, and relevance of evidence from studies done in other countries. The other 2 studies commented on consistency of application of the intervention and differences in personalities when multiple academic detailers are involved.

#### Sustainability

Follow-up periods ranged from one to 4 years post-intervention. Two studies found post-intervention gains were lost by 12 months while 4 studies found improvements that were maintained for as long as 4 years. One study with a mean follow-up of 3.7 years found sustained benefit of communication skills training but not CRP testing.

## DISCUSSION

Our review of recent evidence found generally low strength evidence that stewardship interventions (including provider and/or patient education, guidelines, delayed prescribing, and computerized clinical decision support) are associated with changes in antimicrobial prescribing. The exceptions were medium strength of evidence for the association of communications skills training and laboratory testing with reduced antimicrobial use. Changes in prescribing did not adversely affect patient outcomes or drug costs, where reported. Strength of evidence was low for patient outcomes (return clinic visits and hospitalizations) for provider and/or patient education, delayed prescribing, communications skills training, formulary restriction, decision support, and laboratory testing with insufficient evidence for provider feedback, guidelines, and financial incentives. There was insufficient evidence for the effect of outpatient stewardship interventions on microbial outcomes as no study reported these outcomes (Tables 13 and 14).

Our findings update and generally are consistent with an existing AHRQ Technical Review13,16,17 of studies published to 2007. The AHRQ review found that quality improvement strategies were moderately effective in decreasing inappropriate antimicrobial prescribing and improving appropriate antimicrobial selection. The review included studies of adults and children with any acute infection. The focus was on 6 quality improvement strategies: clinician education, patient education, delayed prescription, audit and feedback, clinician reminders and decision support systems, and financial and regulatory incentives or disincentives. The authors found no definitive evidence of one strategy being superior to another although in studies focused on reducing unnecessary prescribing, “active” education (ie, academic detailing and consensus building) interventions were more effective than “passive” education (ie, distribution of educational materials, lectures) interventions and for studies focused on improving the selection of an antimicrobial, the addition of audit and feedback was less effective than clinician education alone. The authors identified potential confounding factors and noted that the overall quality of the studies was fair.

Many of the interventions evaluated in the recent evidence and the AHRQ review were multifaceted. Although a few studies provided separate results for different intervention components, in most studies, the effects of different intervention components could not be distinguished. An analysis of data from 12 studies that looked at general practitioners' views of antimicrobial prescribing and/or interventions directed at improving prescribing, several of which were related to intervention studies included in our review, provides insight on several elements of intervention programs.82 Providers thought that management of acute respiratory tract infection was complex. Their perceptions of the importance of antimicrobial resistance, past experience with withholding antimicrobials, external pressure to reduce prescribing, and potential conflicts with patients were noted. Providers recognized the potential value of guidelines but were not always trusting of the information contained in the guidelines and the relevance to their patients. Antimicrobial stewardship interventions were viewed as opportunities to reflect on prescribing patterns (through personal and local feedback), aids to decrease uncertainty (through guidelines for diagnosis and/or management), opportunities for learning (particularly discussions with peers creating a uniform practice), facilitators of more patient-centered care (through opportunities to educate patients and better understanding of patient wishes), and ways to possibly reduce workload (although there were concerns about the possibility of additional costs and longer consultation times). For an intervention to change prescribing behavior, it must be acceptable to providers and it must be feasible to put into practice.82

A report from the 2002 International Forum on Antibiotic Resistance (IFAR) colloquium concluded that interventions should focus on changing behavior rather than simply providing information.83 One of the key features of an intervention considered likely to improve antimicrobial use was planning and stakeholder support. This included baseline assessment of provider and public knowledge, attitudes and behaviors; information directed to health professionals, parents, educators, and day-care providers; stakeholder involvement in developing the intervention; and timing the intervention to coincide with peak infection season (ie, for respiratory tract infections). Another feature was the message. The information should be clear, consistent, and positive (eg, bacterial vs viral infections, treatment of symptoms). The third feature was communication. A multi-media and multicultural approach was recommended with focus groups to help refine the educational materials, use of spokespersons to deliver the messages, and academic detailing for healthcare providers. The final feature was evaluation. It was suggested that an intervention project have realistic endpoints, use an appropriate study design, and provide feedback to health care professionals.

A recent invited commentary offered suggestions for changing prescribing behaviors for patients with acute respiratory infections and advancing knowledge about effectiveness of interventions.84 It was suggested that communication with patients emphasize benefits and risks of antimicrobial use. Specifically, the benefits gained (a short reduction in symptoms) must be weighed against the risks (adverse reaction to medication with possible serious adverse event requiring an emergency department visit). It was also suggested that continuous quality improvement approaches might provide more valuable information than randomized trials. With continuous measurement of results, interventions could be modified or new components added in an attempt to improve the prescribing outcomes. Physicians should also explore types of interventions used to effect change in business or psychology.

## LIMITATIONS

The AHRQ Technical Review13 identified limitations of the studies included in the review. Our update of the literature confirms that many of the limitations remain unaddressed. Harms associated with antimicrobial stewardship efforts, including additional utilization of healthcare services and adverse events due to under-treatment, were rarely reported. Few studies reported patient satisfaction with care. We found no studies that reported microbial outcomes. Reporting of costs was limited and typically included only drug costs rather than costs associated with implementation of the intervention and a cost-benefit analysis. As noted above, most of the interventions were multifaceted making specific recommendations about key components difficult. Resources required for program implementation were not reported. Little information was available about stewardship programs in outpatient settings other than primary care or for patient conditions other than respiratory infections. Although several studies provided follow-up data, findings were mixed and conclusions about long-term effects of interventions are not possible. Similarly, the ability to implement interventions on a wide scale has not been addressed.

## FUTURE RESEARCH RECOMMENDATIONS

Our review highlights reduced prescribing associated with stewardship interventions. Future research might look at ways to enhance outpatient antimicrobial stewardship by involving infectious disease specialists and clinical pharmacists in the prescribing decision at the point-of-service via electronic interface or using automated surveillance techniques to monitor patient progress. Future studies should also focus on differences in clinically-meaningful endpoints such as return clinic visits, emergency department visits, adverse drug events, and duration of illness. Large healthcare systems might introduce new stewardship programs in a staggered manner, randomizing facilities to different roll-out times and collecting data as the roll-out proceeds, allowing for a block-randomized trial while instituting a stewardship program. To achieve large sample sizes needed to adequately assess patient outcomes, we recommend a collaborative approach with large healthcare institutions working together.