# REFERENCES

1 Godlee F. Antimicrobial resistance – an unfolding catastrophe. BMJ. 2013;346:f1663.
2 Fairlie T, Shapiro DJ, Hersh AL, Hicks LA. National trends in visit rates and antibiotic prescribing for adults with acute sinusitis. Arch Intern Med. 2012;172:1513-4. [pmid: 23007315].
3 Smith SS, Kern RC, Chandra RK, Tan BK, Evans CT. Variations in antibiotic prescribing of acute rhinosinusitis in United States ambulatory settings. Otolaryngol Head Neck Surg. 2013;148:852-9. [pmid: 23462657].
4 Barnett ML, Linder JA. Antibiotic prescribing to adults with sore throat in the United States, 1997-2010. JAMA Intern Med. 2013. Oct. 3. [doi: 10.1001/jamainternmed.2013.11673]. Epub ahead of print.
5 Costello C, Metcalfe C, Lovering A, Mant D, Hay AD. Effect of antibiotic prescribing in primary care on antimicrobial resistance in individual patients: systematic review and meta-analysis. BMJ. 2010;340:c2096. [pmid: 20483949].
6 MacDougall C, Polk RE. Antimicrobial stewardship programs in health care systems. Clin Microbiol Rev. 2005;18:638-56. [pmid: 16223951].
7 Dellit TH, Owens RC, McGowan JE Jr, Gerding DN, Weinstein RA, Burke JP. Infectious Diseases Society of America and the Society for Healthcare Epidemiology of America guidelines for developing an institutional program to enhance antimicrobial stewardship. Clin Infect Dis. 2007;44:159-77. [pmid: 17173212].
8 Jacob JT, Gaynes RP. Emerging trends in antibiotic use in US hospitals: quality, quantification and stewardship. Expert Rev Anti Infect Ther. 2010;8:893-902. [pmid: 20695745].
9 Ohl CA, Dodds Ashley ES. Antimicrobial stewardship programs in community hospitals: the evidence base and case studies. Clin Infect Dis. 2011;53(Suppl 1):S23-8. [pmid: 21795725].
10 Fishman N. Antimicrobial stewardship. Am J Med. 2006;119(6A):S53-S61. [pmid: 16735152].
11 Avorn J, Solomon DH. Cultural and economic factors that (mis)shape antibiotic use: the nonpharmacologic basis of therapeutics. Ann Intern Med. 2000;133:128-35. [pmid: 10896639].
12 Filice G, Drekonja D, Greer N, Butler M, Wagner B, MacDonald R, Carlyle M, Rutks I, Wilt T. Antimicrobial Stewardship Programs in Inpatient Settings: A Systematic Review. Washington (DC). Department of Veterans Affairs. 2013.
13 Ranji SR, Steinman MA, Shojania KG, et al. Antibiotic Prescribing Behavior. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04(06)-0051-4. Rockville, MD. Agency for Healthcare Research and Quality. January. 2006;4.
14 Davey P, Brown E, Fenelon L, et al. Interventions to improve antibiotic prescribing practices for hospital inpatients. Cochrane Database Syst Rev. 2005;(4). Art. No.: CD003543.
15 Arnold SR, Straus SE. Interventions to improve antibiotic prescribing practices in ambulatory care. Cochrane Database Syst Rev. 2005;(4). Art. No.: CD003539.
16 Ranji SR, Steinman MA, Shojania KG, Gonzales R. Intervention to reduce unnecessary antibiotic prescribing: A systematic review and quantitative analysis. Med Care. 2008;46:847-62. [pmid: 18665065].
17 Steinman MA, Ranji SR, Shojania KG, Gonzales R. Improving antibiotic selection: A systematic review and quantitative analysis of quality improvement strategies. Med Care. 2006;44:617-28. [pmid: 16799356].
18 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
19 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions – Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2010;63:513-23. [pmid: 19595577].
20 Gerber JS, Prasad PA, Fiks AG, et al. Effect of an outpatient antimicrobial stewardship intervention on broad-spectrum antibiotic prescribing by primary care pediatricians: a randomized trial. JAMA. 2013;309:2345-52. [pmid: 23757082].
21 Vinnard C, Linkin DR, Localio AR, et al. Effectiveness of interventions in reducing antibiotic use for upper respiratory infections in ambulatory care practices. Popul Health Manag. 2013;16:22-7. [pmid: 23113630].
22 Butler CC, Simpson SA, Dunstan F, et al. Effectiveness of multifaceted educational programme to reduce antibiotic dispensing in primary care: practice based randomized controlled trial. BMJ. 2012;233:d8173. [pmid: 22302780].
23 Llor C, Cots JM, López-Valcárcel BG, et al. Interventions to reduce antibiotic prescription for lower respiratory tract infections: Happy Audit study. Eur Respir J. 2012;40:436-41. [pmid: 22183489].
24 Llor C, Bjerrum L, Arranz J, et al. C-reactive protein testing in patients with acute rhinosinusitis leads to a reduction in antibiotic use. Fam Pract. 2012;29:653-8. [pmid: 22447979].
25 Regev-Yochay G, Raz M, Dagan R, et al. Reduction in antibiotic use following a cluster randomized controlled multifaceted intervention: the Israeli judicious antibiotic prescription study. Clin Infectious Dis. 2011;53:33-41.
26 Esmaily HM, Silver I, Shiva S, et al. Can rational prescribing be improved by an outcome-based educational approach? A randomized trial completed in Iran. J Contin Educ Health Prof. 2010;30:11-8. [pmid: 20222036].
27 Smeets HM, Kuyvenhoven MM, Akkerman AE, et al. Intervention with educational outreach at large scale to reduce antibiotics for respiratory tract infections: a controlled before and after study. Fam Pract. 2009;26(3):83-7.
28 Finkelstein JA, Huang SS, Kleinman K, et al. Impact of a 16-community trial to promote judicious antibiotic use in Massachusetts. Pediatrics. 2008;121:e15-23. [pmid: 18166533].
29 Chazan B, Turjeman RBZ, Frost Y, et al. Antibiotic consumption successfully reduced by a community intervention program. Isr Med Assoc J. 2007;9:16-20. [pmid: 17274349].
30 Metlay JP, Camargo CA, MacKenzie T, et al., IMPAACT Investigators. Cluster-randomized trial to improve antibiotic use for adults with acute respiratory infections treated in emergency departments. Ann Emerg Med. 2007;50:221-30. [pmid: 17509729].
31 van Driel ML, Coenen S, Dirven K, et al. What is the role of quality circles in strategies to optimize antibiotic prescribing? A pragmatic cluster-randomized controlled trial in primary care. Qual Saf Health Care. 2007;16:197-202. [pmid: 17545346].
32 Varonen H, Rautakorpi UM, Nyberg S, et al., for the MIKSTRA Collaborative Study Group. Implementing guidelines on acute maxillary sinusitis in general practice – a randomized controlled trial. Fam Pract. 2007;24:201-6. [pmid: 17237494].
33 Little P, Rumsby K, Kelly J, et al. Information leaflet and antibiotic prescribing strategies for acute lower respiratory tract infection: a randomized controlled trial. JAMA. 2005;293(24):3029-35. [pmid: 15972565].
34 Pagaiya N, Garner P. Primary care nurses using guidelines in Thailand: a randomized controlled trial. Trop Med Int Health. 2005;10:471-7. [pmid: 15860094].
35 Gonzales R, Sauaia A, Corbett KK, et al. Antibiotic treatment of acute respiratory tract infections in the elderly: effect of a multidimensional educational intervention. J Am Geriatr Soc. 2004;52:39-45. [pmid: 14687313].
36 Stewart J, Pilla J, Lunn L. Pilot study for appropriate anti-infective community therapy: effect of a guideline-based strategy to optimize use of antibiotics. Can Fam Physician. 2000;46:851-9. [pmid: 10790817].
37 Gjelstad S, Høye S, Straand J, Brekke M, Dalen I, Lindbæk M. Improving antibiotic prescribing in acute respiratory tract infections: cluster randomised trial from Norwegian general practice (prescription peer academic detailing (Rx-PAD) study). BMJ. 2013;347:f4403. [pmid: 23894178].
38 Linder JA, Schnipper JL, Tsurikova R, et al. Electronic health record feedback to improve antibiotic prescribing for acute respiratory infections. Am J Manag Care. 2010;16(12 Suppl HIT):e311-9. [pmid: 21322301].
39 Naughton C, Feely J, Bennett K. A RCT evaluating the effectiveness and cost-effectiveness of academic detailing versus postal prescribing feedback in changing GP antibiotic prescribing. J Eval Clin Pract. 2009;15(5):807-12. [pmid: 19811593].
40 Madridejos-Mora R, Amado-Guirado E, Pérez-Rodriguez MT. Effectiveness of the combination of feedback and educational recommendations for improving drug prescription in general practice. Med Care. 2004;42:643-8. [pmid: 15213488].
41 Dowell D, Tian LH, Stover JA, et al. Changed in fluoroquinolone use for gonorrhea following publication of revised treatment guidelines. Am J Public Health. 2012;102:148-55. [pmid: 22095341].
42 Skekovec C, Leroy J, Vernaz-Hegi, et al. Impact of a region wide antimicrobial stewardship guideline on urinary tract infection prescription patterns. Int J Clin Pharm. 2012;34:325-9. [pmid: 22252772].
43 Venekamp RP, Rovers MM, Verheij THJ, Bonten MJM, Sachs APE. Treatment of acute rhinosinusitis: discrepancy between guideline recommendations and clinical practice. Fam Pract. 2012;29:706-12. [pmid: 22389427].
44 Weiss K, Blais R, Fortin A, Lantin S, Gaudet M. Impact of a multipronged education strategy on antibiotic prescribing in Quebec, Canada. Clin Infectious Dis. 2011;53:433-9.
45 Seager JM, Howell-Jones RS, Dunstan FD, Lewis MAO, Richmond S, Thomas DW. A randomised controlled trial of clinical outreach education to rationalise antibiotic prescribing for acute dental pain in the primary care setting. Br Dent J. 2006;201(4):217-22. [pmid: 16902573].
46 Martens JD, Winkens RAG, van der Weijden T, de Bruyn D, Severens JL. Does a joint development and dissemination of multidisciplinary guidelines improve prescribing behaviour: a pre/post study with concurrent control group and a randomised trial. BMC Health Serv Res. 2006;6:145. [pmid: 17081285].
47 Little P, Moore MV, Turner S, et al. Effectiveness of five different approaches in management of urinary tract infections: randomised controlled trial. BMJ. 2010;340:c199. [pmid: 20139214].
48 Worrall G, Kettle A, Graham W, Hutchinson J. Postdated versus usual delayed antibiotic prescriptions in primary care. Can Fam Physician. 2010;56:1032-6. [pmid: 20944049].
49 Little P, Stuart B, Francis N, et al., on behalf of the GRACE consortium. Effects of internet-based training on antibiotic prescribing rates for acute respiratory-tract infections: a multinational cluster, randomised, factorial, controlled trial. Lancet. ePub 31 July 2013.
50 Légaré F, Labrecque M, Cauchon M, Castel J, Turcotte S, Grimshaw J. Training family physicians in shared decision-making to reduce the overuse of antibiotics in acute respiratory infections: a cluster randomized trial. CMAJ. 2012;184(13):E726-34. [pmid: 22847969].
51 Légaré F, Labrecque M, LeBlanc A, et al. Training family physicians in shared decision making for the use of antibiotics for acute respiratory infections: a pilot clustered randomized controlled trial. Health Expect. 2010;14(Suppl 1):96-110. [pmid: 20629764].
52 Cals JW, Butler CC, Hopstaken RM, Hood K, Dinant GJ. Effect of point of care testing for C reactive protein and training in communication skills on antibiotic use in lower respiratory tract infections: cluster randomised trial. BMJ. 2009;338:b1374. [pmid: 19416992].
53 Cals JW, Ament AJ, Hood K, et al. C-reactive protein point of care testing and physician communication skills training for lower respiratory tract infections in general practice: economic evaluation of a cluster randomized trial. J Eval Clin Pract. 2011;17(6):1059-69. [pmid: 20666881].
54 Cals JW, deBock L, Beckers P-JHW, et al. Enhanced communications skills and C-reactive protein point of care testing for respiratory tract infection: 3.5 year follow-up of a cluster randomized trial. Ann Fam Med. 2013;11:157-64. [pmid: 23508603].
55 Francis NA, Butler CC, Hood K, Simpson S, Wood F, Nuttall J. Effect of using an interactive booklet about childhood respiratory tract infections in primary care consultations on reconsulting and antibiotic prescribing: a cluster randomised controlled trial. BMJ. 2009;339:b2885. [pmid: 19640941].
56 Altiner A, Brockmann S, Sielk M, Wilm S, Wegscheider K, Abholz H-H. Reducing antibiotic prescriptions for acute cough by motivating GPs to change their attitudes to communication and empowering patients: a cluster-randomized intervention study. J Antimicrob Chemother. 2007;60:638-44. [pmid: 17626023].
57 Manns B, Laupland K, Tonelli M, Gao S, Hemmelgam B. Evaluating the impact of a novel restricted reimbursement policy for quinolone antibiotics: A time series analysis. BMC Health Serv Res. 2012;12:290. [pmid: 22935100].
58 Marshall D, Gough J, Grootendorst P, et al. Impact of administrative restrictions on antibiotic use and expenditure in Ontario: time series analysis. J Health Serv Res Policy. 2006;11(1):13-20. [pmid: 16378528].
59 Gonzales R, Anderer T, McCulloch CE, et al. A cluster randomized trial of decision support strategies for reducing antibiotic use in acute bronchitis. JAMA Intern Med. 2013;173(4):267-73. [pmid: 23319069].
60 Jenkins TC, Irwin A, Coombs L, et al. Effects of clinical pathways for common outpatient infections on antibiotic prescribing. Am J Med. 2013;126:327-35. [pmid: 23507206].
61 McGinn TG, McCullagh L, Kannry J, et al. Efficacy of an evidence-based clinical decision support in primary care practices. A randomized clinical trial. JAMA Intern Med. ePub 29 July 2013.
62 Rattinger GB, Mullins CD, Zukerman IH, et al. A sustainable strategy to prevent misuse of antibiotics for acute respiratory infections. PLoS ONE. 2012;7(12):e51147. [pmid: 23251440].
63 Linder JA, Schnipper JL, Tsurikova R, et al. Documentation-based clinical decision support to improve antibiotic prescribing for acute respiratory infections in primary care: a cluster randomised controlled trial. Inform Prim Care. 2009;17(4):231-40. [pmid: 20359401].
64 Martens JD, van der Weijden T, Severens JL, et al. The effect of computer reminders on GPs' prescribing behaviour: a cluster-randomised trial. Int J Med Inform. Suppl 3. 2007;76:S403-16. [pmid: 17569575].
65 Martens JD, Werkhoven MJ, Severens JL, Winkens RAG, et al. Effects of a behaviour independent financial incentive on prescribing behaviour of general practitioners. J Eval Clin Pract. 2007;13(3):369-73. [pmid: 17518801].
66 Little P, Hobbs FDR, Moore M, et al. Clinical score and rapid antigen detection test to guide antibiotic use for sore throats: randomized controlled trial of PRISM (primary care streptococcal management). BMJ. 2013;347:f5806. [pmid: 24114306].
67 Brittain-Long R, Westin J, Olofsson S, Lindh M, Andersson LM. Access to a polymerase chain reaction assay method targeting 13 respiratory viruses can reduce antibiotics: a randomised, controlled trial. BMC Med. 2011;9:44. [pmid: 21521505].
68 Worrall G, Hutchinson J, Sherman G, Griffiths J. Diagnosing streptococcal sore throat in adults: randomized controlled trial of in-office aids. Can Fam Physician. 2007;53:666-71. [pmid: 17872717].
69 Diederichsen HZ, Skamling M, Diederichsen A, et al. Randomised controlled trial of CRP rapid test as a guide to treatment of respiratory infections in general practice. Scand J Prim Health Care. 2000;18(1):39-43. [pmid: 10811042].
70 Takemura Y, Ebisawa K, Kakoi H, et al. Antibiotic selection patterns in acutely febrile new outpatients with or without immediate testing for C reactive protein and leucocyte count. J Clin Pathol. 2005;58(7):729-33. [pmid: 15976341].
71 Cals JW, Schot MJ, de Jong SA, Dinant GJ, Hopstaken RM. Point-of-care C-reactive protein testing and antibiotic prescribing for respiratory tract infections: a randomized controlled trial. Ann Fam Med. 2010;8(2):124-33. [pmid: 20212299].
72 Moore M, Little P, Rumsby K, Kelly J, et al. Effect of antibiotic prescribing strategies and an information leaflet on longer-term reconsultation for acute lower respiratory tract infection. Brit J Gen Pract. 2009;59:728-34. [pmid: 19843421].
73 Schuetz P, Miller B, Christ-Crain M, Stoltz D, Tamm M, Bouadma L. Procalcitonin to initiate or discontinue antibiotics in acute respiratory tract diseases. Cochrane Database of Systematic Reviews. 2012;(9). Art. No.: CD007498. [doi: 10.1002/14651858.CD007498.pub2].
74 Aagaard EM, Gonzales R, Camargo CA, et al. Physician champions are key to improving antibiotic prescribing quality. Jt Comm J Qual Patient Saf. 2010;36(3):109-16. [pmid: 20235412].
75 Stille CJ, Rifas-Shiman SL, Kleinman K, Kotch JB, Finkelstein JA. Physician response to a community-level trial promoting judicious antibiotic use. Ann Fam Med. 2008;6:206-12. [pmid: 18474882].
76 Frich JC, Høye S, Lindbæk M, Straand J. General practitioners and tutors' experiences with peer group academic detailing: a qualitative study. BMC Fam Pract. 2010;11:12. [pmid: 20152015].
77 Mann DM, Kannry JL, Edonyabo D, et al. Rationale, design, and implementation protocol of an electronic health record integrated clinical prediction rule (iCPR) randomized trial in primary care. Implement Sci. 2011;6:109. [pmid: 21929769].
78 LeBlanc A, Légaré F, Labrecque M, et al. Feasibility of a randomized trial of a continuing medical education program in shared decision-making on the use of antibiotics for acute respiratory infections in primary care: the DECISION+ pilot trial. Implement Sci. 2011;6:5. [pmid: 21241514].
79 Allaire A-S, Labrecque M, Giguere A, Gagnon M-P, Légaré F. What motivates family physicians to participate in training programs in shared decision making?. J Contin Educ Health Prof. 2012;32:98-107. [pmid: 22733637].
80 Welschen I, Kuyvenhoven MM, Hoes AW, Verheij TJM. Effectiveness of a multiple intervention to reduce antibiotic prescribing for respiratory tract symptoms in primary care: randomised controlled trial. BMJ. 2004. [doi: 10.1136/bmj.38182.591238.EB].
81 Anthierens S, Tonkin-Crine S, Douglas E, et al., GRACE INTRO study team. General practitioners' views on the acceptability and applicability of a web-based intervention to reduce antibiotic prescribing for acute cough in multiple European countries: a qualitative study prior to a randomized trial. BMC Fam Pract. 2012;13:101. [pmid: 23110756].
82 Tonkin-Crine S, Yardley L, Little P. Antibiotic prescribing for acute respiratory tract infections in primary care: a systematic review and meta-ethnography. J Antimicrob Chemother. 2011;66:2215-23. [pmid: 21764827].
83 Finch RG, Metlay JP, Davey PG, Baker LJ, for the International Forum on Antibiotic Resistance colloquium (2002). Educational interventions to improve antibiotic use in the community: report from the International Forum on Antibiotic Resistance colloquium, 2002. Lancet. 2004;4:44-53. [pmid: 14720568].
84 Linder JA. Antibiotic prescribing for acute respiratory infections – success that's way off the mark. JAMA Intern Med. 2013;173:273-6. [pmid: 23318503].