# METHODS

## TOPIC DEVELOPMENT

Our key questions were developed with input from a technical expert panel.

The final key questions are:

Key Question 1. What is the effectiveness of antimicrobial stewardship programs in outpatient settings on the following:

a. Primary Outcome: Antimicrobial prescribing (decision to prescribe, selection of antimicrobial, duration of treatment, guideline concordant use)
b. Secondary Outcomes: 1) Patient centered outcomes (return clinic visit, hospital admission, adverse events, late antimicrobial prescription, patient satisfaction with care); 2) Microbial outcomes (resistance in study population); 3) Costs (program costs, drug costs)?

Key Question 2. What are the key intervention components associated with effective outpatient antimicrobial stewardship (eg, type of intervention; personnel mix; level of support)?

Key Question 3. Does effectiveness vary by a) clinic type or setting (primary care clinic vs emergency department or urgent care; VA, non-VA) or b) suspected patient condition (respiratory tract infections, urinary tract infections, soft-tissue infections)?

Key Question 4. What are the harms of antimicrobial stewardship programs in outpatient settings?

Key Question 5. Within the included studies, what are the barriers to implementation, sustainability, and scalability of antimicrobial stewardship programs in outpatient settings?

## SEARCH STRATEGY

The literature search for this review was conducted concurrently with the literature search for our review of inpatient ASPs.12 An exploratory search identified 2 relevant Cochrane reviews that partially addressed the key questions but were no longer current.14,15 We used a search strategy similar to that of the Cochrane reviews to search MEDLINE (Ovid) from 2000 through November 2013. We limited the search to studies in English language, and enrolling human subjects. Our search included terms for antimicrobial agents (eg, anti-bacterial agents, anti-infective agents), infection types, and program implementation (eg, guideline implementation, practice patterns). The full search strategy is presented in Appendix A. Additional citations were identified from systematic reviews, reference lists of retrieved articles, and suggestions made by our technical expert panel members and peer reviewers.

## STUDY SELECTION

Titles, abstracts, and articles were reviewed by investigators and research associates trained in the critical analysis of literature. During title and abstract review, we identified studies conducted in both inpatient and outpatient settings. We excluded studies for the following reasons and identified for full text review any articles that either did not fall into one of these categories or for which there was uncertainty about eligibility:

1. Study not published in English language;
2. Study done in nursing home (long-term care) setting;
3. Study not about antimicrobial stewardship;
4. Study of antimicrobials for medical or surgical prophylaxis;
5. Study of patients with viral or fungal infection or tuberculosis;
6. Study not involving an intervention or not involving an intervention of interest; patient education programs were included; community/public health campaigns were excluded;
7. Description of an intervention with no assessment of the effect of the intervention;
8. Study design OTHER THAN randomized, controlled trial (RCT), cluster randomized controlled trial (CRCT), controlled clinical trial (CCT), controlled before/after study (CBA), or interrupted time series (ITS) with at least 3 time points before and after implementation of the intervention; and
9. No outcomes of interest; outcomes of interest are a) antimicrobial prescribing (eg, decision to prescribe, selection of antimicrobial, duration of treatment, guideline concordant use), b) patient-centered outcomes (eg, return clinic visits, hospital admission, adverse events, late antimicrobial prescriptions, patient satisfaction with care), c) microbial outcomes (resistance in study population), d) cost (program costs, drug costs), and e) other (process, sustainability, scalability etc.).

We reviewed full text versions of potentially eligible articles and excluded studies that met any of the criteria outlined in items 1 to 9 above. We also added the following exclusion criterion: study done in setting not relevant to medicine in the United States or involving a population or infectious disease not relevant to United States population.

To avoid overlap with the existing AHRQ review, we excluded any studies cited in the full Technical Review13 or the related publications.16,17

## DATA ABSTRACTION

We categorized ASP interventions based on the primary emphasis of the intervention as described by the study author: provider and/or patient education, provider feedback, guidelines, delayed prescribing, communications skills training, restriction, decision support, financial incentives, and laboratory testing.

From studies identified as eligible after full-text review we extracted the following:

1. Study characteristics – study design, geographic region, intervention(s), comparator(s), intervention staff (to develop and implement the intervention), resources (ie, hardware or software used or purchased, staff hired), site, patient characteristics (number, age), exclusion criteria, recruitment, and randomization unit (for RCTs and CRCTs);
2. Antimicrobial prescribing outcomes – percent prescribed antimicrobial, selection, duration, guideline concordant use;
3. Patient outcomes – return clinic visits, hospitalizations, adverse events, late antimicrobial prescriptions, patient satisfaction with care;
4. Microbial outcomes – resistance in the study population;
5. Costs – dispensing costs, program costs;
6. Harms of stewardship program implementation; and
7. Other – barriers to implementation, sustainability and scalability of intervention.

From each study, we extracted all data fitting the descriptions of the outcomes in the list above including multiple outcomes, if provided. For ITS studies, we report, where provided by study authors, level and trend (or slope) results. Level refers to the change in the value of the outcome measure from pre- to post-intervention. Trend refers to the change between the slope of the line through data points before the intervention and the line through data points after the intervention.

## QUALITY ASSESSMENT

We assessed the risk of bias of individual studies using the criteria developed for use in Cochrane Effective Practice and Organization of Care (EPOC) reviews (Appendix B). There are 9 criteria for assessing risk of bias for studies with a separate control group (ie, RCTs, CCTs, and CBA studies) and 7 criteria for assessing risk of bias for ITS studies. Each element is scored as high, unclear, or low risk. A study was rated as low risk of bias if each of the individual criteria were scored as low risk, medium risk of bias if one or 2 criteria were scored as unclear or high risk, and high risk of bias if more than 2 criteria were scored as unclear or high risk.

Quality of systematic reviews was determined using the measurement tool for assessment of multiple systematic reviews (AMSTAR).18

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included studies, organized by intervention category. We critically analyzed studies to compare their characteristics, methods, and findings. However, due to heterogeneity of interventions, study designs, patient populations, and outcomes reporting among studies for an intervention, the results cannot be meaningfully pooled. Therefore, we compiled a summary of findings for each key question and drew conclusions based on qualitative synthesis of the findings.

## RATING THE BODY OF EVIDENCE

We rated overall strength of evidence for our patient outcomes for each intervention category using methods developed by AHRQ and the Effective Health Care Program. 19 The strength of the evidence was evaluated based on 4 domains: 1) risk of bias (whether the studies for a given outcome or comparison have good internal validity); 2) consistency (the degree of similarity in the effect sizes, ie, same direction of effect, of the included studies); 3) directness (reflecting a single, direct link between the intervention of interest and the outcome); and 4) precision (degree of certainty surrounding an effect estimate of a given outcome).

## PEER REVIEW

A draft version of this report was reviewed by technical experts as well as clinical leadership. Reviewer comments (Appendix C) were addressed and our responses incorporated in the final report.