# INTRODUCTION

Several factors are contributing to the current antimicrobial crisis which has been labeled “an unfolding catastrophe.”1 The greatest challenges are overuse of existing antimicrobials, increasing resistance to existing agents, the absence of new products, and changes in the types of organisms affected by new agents.

The majority of antimicrobials are prescribed to humans in outpatient settings. Three studies used combined data from the National Ambulatory Medical Care Survey and the National Hospital Ambulatory Care Survey. Of these, 2 recent studies found that over 80% of adult outpatients with rhinosinusitis were prescribed antimicrobials.2,3 The third study reported that although adult primary care visits for sore throat decreased significantly between 1997 and 2010, antimicrobials were prescribed at 60% of the visits and the overall prescribing rate did not change.4 This is despite estimates that approximately 10% of patients with sore throat have group A Streptococcus infection, the only cause of pharyngitis benefitted by antimicrobials.

Several reasons for high prescribing rates for unneeded antimicrobials in outpatient settings have been suggested. In making prescribing decisions, primary care providers are faced with patient expectations, and with patient and provider lack of awareness of antimicrobial resistance and lack of understanding of the seriousness of the antimicrobial resistance problem.5

While increasing antimicrobial resistance is often thought of as a population-based problem, individual antimicrobial resistance has also been shown to be associated with prior exposure to antimicrobials. A recent systematic review focused on the effects of antimicrobial use on the emergence of resistance for individual patients.5 Twenty-four studies (5 RCTs and 19 observational studies) were eligible for the review. For urinary isolates, exposure to antimicrobials was associated with increased odds of resistance compared to no exposure. At 3 months, based on pooled data from 3 studies (4 comparisons) the odds ratio was 2.48 (95% CI 2.06, 2.98) with I^2^=0%. In 3 studies (5 comparisons) with data at 12 months, there was greater heterogeneity (I^2^=72%) but the odds of resistance associated with exposure to antimicrobials were still significant (OR 1.33 [95% CI 1.15, 1.53]). For respiratory isolates, the odds of resistance associated with exposure were significantly higher at 1 month (1 study; OR 2.10 [95% CI 1.04, 4.23]), 2 months (2 studies; OR 2.37 [95% CI 1.42, 3.95], I^2^=2%) and 12 months (3 studies; 6 comparisons, OR 2.7 [95% CI 1.25, 4.50], I^2^=57.3%) but not at 3 months (2 studies, 4 comparisons) or 6 months (1 study, 2 comparisons).

## ANTIMICROBIAL STEWARDSHIP PROGRAMS

An antimicrobial stewardship program (ASP) is a focused effort by a healthcare organization or a portion of an organization (ie, a primary care clinic) to optimize antimicrobial use for the purposes of improving patient outcomes, reducing adverse consequences, and delivering cost-effective therapy.6-9 The emphasis is on appropriate selection, dosing, and duration of antimicrobial therapy.7,9

In hospital settings, strategies for improving antimicrobial stewardship typically involve prospective audit and feedback, formulary restriction, pre-authorization of prescriptions, guidelines for prescribing and/or modifying therapy, and education.7,10 A comprehensive ASP may include some or all of the following:7,10,11

- a multidisciplinary team consisting of infectious disease physicians, clinical pharmacists, clinical microbiologists, information system specialists, infection control specialists, and hospital epidemiologists;
- collaboration between the ASP team and hospital infection control and pharmacy and therapeutics committees;
- support and collaboration of hospital administrators, medical staff leadership, and local providers;
- hospital administrative support for computer systems and other resources to improve decision making, measure and track antimicrobial use, track resistance patterns, and identify hospital-based infections and adverse drug events; and
- a microbiology laboratory to provide patient-specific data for optimizing treatment, surveillance of resistant organisms, and molecular-level investigation of outbreaks.

Due to the nature of the patient encounter, ASPs in outpatient settings may emphasize additional elements (eg, patient education, communication skills training for providers, delayed prescribing, rapid testing). In many outpatient prescribing situations, the prescribing decision will be made without input from a team of specialists, the provider may not have an opportunity to modify the initial prescription, and provider may not receive feedback on the patient's progress.

## PURPOSE AND SCOPE OF REVIEW

The purpose of this review is to synthesize the evidence about the effectiveness of ASPs implemented in outpatient settings. The topic was nominated by Matthew Goetz, MD, Chief, Infectious Diseases, VA Greater Los Angeles Healthcare System, on behalf of the VA Antimicrobial Stewardship Task Force, and the review is intended to provide a summary of the evidence on outpatient ASPs to guide clinical practice and policy within the Veterans Healthcare System. This review is a companion to a recently completed review on ASPs in inpatient settings.12

We focus on outpatient settings with patients of all ages and limit our review to randomized controlled trials (RCTs), controlled clinical trials (CCTs), controlled before and after studies (CBAs), and interrupted time series (ITS) analyses with data for at least 3 time points before and after the intervention. Our main outcomes of interest for this review were antimicrobial prescribing outcomes (ie, the percentage of patient receiving antimicrobials after an initial consultation for a possible infectious condition in an outpatient setting and the selection of an appropriate antimicrobial). We also report patient-centered outcomes, microbial outcomes, costs, harms of stewardship programs, key intervention components, and barriers to implementation, sustainability, and scalability. We summarize the findings from a prior Agency for Healthcare Research and Quality (AHRQ) Technical Review that included studies published through 2004^13^ and focus on studies published since the time of that review or not included in the review.