# EVIDENCE TABLES

Table 1 Study Characteristics

Table 2 Study Characteristics, Continued

Table 3 Prescribing Outcomes

Table 4 Patient Outcomes

Table 5 Cost and Harms Outcomes

Table 6 Risk of Bias Assessment for RCT, CCT, and CBA Studies

Table 7 Risk of Bias Assessment for ITS Studies