# PEER REVIEW COMMENTS/AUTHOR RESPONSES

REVIEWER COMMENT | RESPONSE
1. Are the objectives, scope, and methods for this review clearly described?
Yes. Very thoroughly described objectives and methodology. They have used strict criteria on randomized controlled trials, cluster randomization and interval time series analysis studies, Excluding retrospective analyses with all their flaws and bias with these studies is appropriate. The studies are mostly current (<10 years old) which is critical for determining relevance to current clinical practice. Breaking down the studies into their purpose, outcomes and strength in the tables makes it easier to review than the long discussions. Another strength is also grouping studies on type of intervention (lab, provider education etc) can really relate the type of studies to likely clinical outcomes. | Thank you.
Yes
Yes. The review is extremely well-organized, with clear objectives and scope. Methods are also transparent, particularly in how the prior AHRQ review is discussed in relation to the data the authors find that correspond to each category of analysis. I particularly appreciated the authors separating out communication skills training as a category of analysis; this may be a particularly fruitful area for further research in antimicrobial stewardship. | Thank you.
Yes
Yes. Well structured and organized | Thank you.
Yes
2 Is there any indication of bias in our synthesis of the evidence?
No. All studies selected are appropriate. I performed a current pubmed search and saw no papers missing from this analysis. Knowing some of these papers from having reviewed them for journals, you have identified the critical issues (Legare especially – several papers of this author have not been published I have reviewed due to errors you have identified). The evidence is as you state – limited for all types of interventions and with end points that are short term. There are no data on how these interventions look one-2 years later. Defining the optimal intervention is also limited by lack of data strength especially for scalability and mostly sustainability of the intervention. | Thank you. Please note that we have updated our literature search and added 3 references.
No
No. I continue to be surprised at the rather high level of bias present in the majority of the studies analyzed, as assigned by the authors of the review. I am also surprised that only 2 studies that addressed formulary restriction were of significant quality to include in the review. | We, too, are disappointed in the high level of bias. Of note, the AHRQ review also identified only one study of a restrictive intervention.
Yes. Not including studies that were in the AHRQ review and only including recent studies (noting, however, the older Cochrane review studies that were analyzed separately) may have biased the outcomes. | We attempted to provide sufficient information about the studies included in the AHRQ review (and the findings). The 2 Procalcitonin studies from the Cochrane review on that topic were also fairly recent studies (2008 and 2010).
No. Comments: p. 26, line 28-31: “It is unlikely that there will be a team of specialists involved in the prescribing decision, unlikely the provider will have an opportunity to modify the initial prescription, and unlikely the provider will receive feedback on the patient's progress.” The above statement does not reflect the recognition that experts can deliver evidence-based recommendations at the point-of-service through electronic means, or that automated surveillance methods can follow the progress of individual patients. In general, the review could expand its underlying vision of how a team of specialists could deliver effective, sustainable and scalable outpatient antibiotic stewardship. | Thank you. We have modified the statement cited to reflect that in “many outpatient situations” these factors may apply and included a sentence about improving prescribing and monitoring in the Future Research section.
No
3 Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
No
Yes. Cals JW et al. Point-of-Care C-Reactive Protein Testing and Antibiotic Prescribing for Respiratory Tract Infections: A Randomized Controlled Trial Ann Fam Med March 1, 2010 vol. 8 no. 2 124-133 | Thank you. This trial was already included in the review.
No. The studies that I previously suggested for inclusion appear to have been considered by the authors. I have no new studies to suggest. | Thank you.
No. None that met the strict criteria for entry. | Thank you.
No. The review's choice to leverage existing reviews and focus on the latest additions to the literature is both wise and well implemented. I am not aware that the evidence review has missed a meaningful entry. The following are a few note/errors noted in the reference section: p. 85, line 7: I cannot find this reference in PubMed p. 85, line 29: Labracque should read Labrecque p. 88, line 41: Blair should read Blais | Thank you. The reference noted on page 85, line 7 (the Godlee 2013 reference) is correct but is not cited in PubMed. We have corrected the typographical errors on the other 2 references.
No. Not that I am aware of although I did not review the literature comprehensively. | Thank you.
4 Please write any additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
None, very thorough review and conclusions. Areas that should have been also considered for future evaluation include routine urine cultures and treatment of asymptomatic bacteruria in outpatient settings and pre-operative clinics (See Drekonja JAMA 2013) as a future intervention and target for stewardship. As this is in the outpatient setting the data is limited compared to the vast inpatient literature where there is more “control” for antibiotic use in larger centers | Thank you. This may be a topic for future intervention but, at present, we found no studies. The reference cited (actually in Archives of Internal Medicine) would not have been eligible for inclusion in the review.
Executive Summary table 2a: what does “+-/-“ signify – this is not defined in the table legend Page 39, line 28: agree that the duration of follow-up and sustainability of the cited 9.7% reduction of antimicrobial use should be provided | Executive Summary Table 2a: We have added the definition of +/-to the table legend. Page 39: We have added the follow-up information for this outcome.
Page 4, lines 2-6, 28, 29: When ranges are presented (ie “ranging from 0.2% to 10.5%” (line 2), “ranging from 0.3% to 55.0%” (line 3), “ranging from 15-75%” (lines 5-6), “1.4%-13.1%” (line 28), “10.4%-44.5% (line 29)), would suggest including medians if possible. Page 34, lines 27-28: Agree that duration of followup and sustainability be addressed if possible. Perhaps give a range/median of duration of followup from the studies in which it was reported. How many studies actually addressed sustainability, though? If not many, maybe it's not worth including. Page 35, line 32: pneumonia should be pneumoniae Page 44, line 16: “twol” should be “two” Page 61, line 43: I'd specifically say here that no other studies addressing procalcitonin beyond the two discussed in the Cochrane review met criteria for inclusion in the current review | Page 4: Thank you. We have added medians. Page 34: We have reported the median length of follow-up. The AHRQ report did not provide information on follow-up in individual studies. It is not possible to determine whether the studies were addressing sustainability. Page 35 and Page 44: we have corrected these errors Page 61: We have added this statement.
I think the rationale for not including studies from the AHRQ review is troublesome to explain; if their methodology otherwise met the criteria of this systematic review, why not include them? Given the population of patients served through the VA system, excluding studies primarily focused on pediatric patient populations would have seemed reasonable. The tables in Appendix D are superb. Please discuss the role of the risk of adverse drug effects, particularly the risk of C. difficile colitis, in projects involving provider and patient education. Was the inclusion of these effects effective in reducing overall antibiotic use? I think the authors should discuss the limitations of this systematic review. In the limitations paragraph on page 82, comments are primarily made towards the limitations of the studies included in the review. The methods of a systematic review may not be the optimal way to address the primary outcomes (key questions) sought for assessing the available literature on outpatient antimicrobial stewardship programs. For instance, a comment is made “most of the interventions were multifaceted making specific recommendations about key components difficult.” The authors seem to fault the studies for this, rather than question whether trying to assess the various outcomes measurements of the studies through a systematic review is the most appropriate venue to assess these studies. Another limitation to address is the methods of the electronic literature search. Despite a thorough vetting of 559 full-text articles, Fifteen (43%) of the 35 studies ultimately included did not come from the electronic literature search, implying that there were possibly flaws in the methods of the literature search. In addition, there are no comments on whether any other studies reviewed outside of the electronic literature search (ie, suggested by reviewers) were excluded from the analysis. I'm concerned that some interventions in certain studies that demonstrated statistically significant improvements in outcomes were dismissed by the authors due to the extent of the improvement rather than the four domains described the section “rating the body of evidence” (page 31). For instance, many studies showed statistically significant improvements in prescribing habits but since the size of the difference was ∼10% it was subjectively characterized by the authors. I think the interpretation of the extent of statistically significant improvements in an effect should be left to the readers opinion. Finally, a limitation that systematic reviews often have is coming to a conclusion about an outcome without discussing the possibility that certain excluded studies may have added important and valid variables to affect the outcome. It is likely that with over 90% of the full-text articles excluded, at least some of these data would have important findings that would affect the answers to the key questions. This limitation is probably slight in systematic reviews that assess the objective, clear comparative outcomes of “drug A” versus “drug B” for a given disease state, but is probably more important for the key questions addressed in this review. | We decided that including the studies cited in the AHRQ review was a duplication of effort and therefore elected to summarize the findings from that review. In a conference call with our Operational Partners and Technical Expert Panel it was agreed that the pediatric studies should be included because the interventions were relevant to all populations We mentioned the potential for adverse drug effects especially C. difficile colitis. These adverse effects were extracted if reported. We recognize the reviewer's concern and agree that systematic reviews have limitations. Systematic reviews are intended to summarize and synthesize the available evidence on a topic and are therefore limited by the study methods, selected outcomes and outcomes reporting of the original research. Our intention is to highlight for researchers how the design of the existing research (multifaceted interventions, short follow-up periods, etc.) limits what can be concluded about specific interventions, sustainability, etc. At present, there are no Medical Subject Headings (MeSH) terms for searching in MEDLINE that directly pertain to antimicrobial stewardship. We modeled our search after searches in existing reviews. We also reviewed reference lists of existing reviews and included studies. For this review, only one reference was suggested by reviewers and this reference was already included in the review. We have provided the reader with the findings from the individual studies and then determined an overall strength of evidence (Executive Summary Table 3a) taking into account risk of bias, consistency, directness and precision. Certainly there is a large body of literature on antimicrobial stewardship that was excluded from our review. The most common reason for excluding studies was the study design. We chose to focus on the studies with the lowest potential for bias and therefore believe we have captured the most important evidence on the topic.
1. The review categorizes stewardship interventions in a manner that more or less follows precedent reviews. The rationale for this categorization is not given. Many of the interventions involve the delivery of guideline-derived education to providers and/or patients. There is no systematic attempt to abstract information about the nature, format, intermediary, timing and periodicity of this education in relation to the provision of care.; 2. Labeling of the “Laboratory Testing” category is not informative. Category label should reflect what is being introduced to the antibiotic prescribing logic: rapid laboratory evidence of either specific infection, or of systemic inflammation.; 3. Evaluation of the evidence supporting an intervention is limited to biases inherent to study design. The review could attempt to better abstract and synthesize other potentially significant markers of intervention utility, such as effect size and sustainability. For example, a VA study that reports a 4-year intervention is not mentioned in the “Sustainability” section. | 1. We attempted to categorize studies by the primary intervention based on the study authors' description of the intervention. We have noted where the interventions were multifaceted. We agree that the factors listed are potentially important in evaluating the effectiveness of the intervention and have attempted to highlight these factors in the report. There is limited information provided on this and goes beyond the scope of our review and input we received from our Technical Expert Panel when constructing the key questions, outcomes and protocol.; 2. We have modified the “Laboratory Testing” section to better characterize the interventions.; 3. We used standard methods (the approach used in the Cochrane Effective Practice and Organization of Care reviews) to evaluate the risk of bias of individual studies. Overall strength of evidence for the interventions was determined based on risk of bias of individual studies plus the consistency and precision of the findings across the studies.; We have added the VA study to the sustainability section.
I know there was some discussion of this, but I don't find studies of children relevant to the VA population. On page 34 there is a comment in the 3rd full paragraph that looks like an unfinished question I still find the format somewhat confusing in differentiating information from the old reviews (AHRQ and Cochrane) versus results from this review. In addition, it would be nice to see a summary including the overall result combining the two for the main outcomes. I said this on the inpatient review as well, but I find the tables very difficult to follow. It would be nice to have a visual summary somewhere – either a boxed off area with summary results or a Forrest plot to see the outcomes in a way that is easy to follow. I find this very useful in the Cochrane analyses which are also very long and comprehensive, but allows for a quick review of the data. I know it is a lot of information, but I wish tables 1-5 were combined. It's difficult to flip back and forth between study design and outcomes for a clinician trying to use this information | As noted above, it was agreed that pediatric studies should be included. Pg. 34 – this has been corrected We chose to categorize interventions somewhat differently than in the AHRQ review therefore it wasn't possible to seamlessly combine the older studies and the newer studies. We have added a summary of the AHRQ review to the Discussion section of both the Executive Summary and full report. Due to the variety of ways the outcomes were reported across studies, we were unable to create forest plots. We have added a key findings section to the Discussion section of the Executive Summary. It would be difficult if not impossible to put sufficient information about study characteristics AND outcomes on a single table. We have considered alternative options but given the volume of information believe the current Tables 1-5 are preferred.
5 Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
Most of studies are on URTI. Would have table showing the data/patient outcomes of not treating versus treating from all the randomized studies. End points may be different but populations wlll be similar. Also would break out (Looks like one asymptomatic bacteruria) study. This is a detailed report and the tables are excellent for reviewing. | Thank you. We included a table that highlighted the non-respiratory infections because they were so few in number. A table of studies with respiratory infections would comprise the bulk of the studies already displayed. Similarly, a table of outcomes of not treating versus treating would be largely duplicative. We believe that additional Tables would not add much value especially for the length and resources involved.
This is a nicely written report. I have no further suggestions | Thank you.
All in all, this report does a nice job of directly addressing implementation needs. I do not think major revisions are necessary. | Thank you.
The authors might expand upon their ideas for future research recommendations. | We have added some additional information to this section.
Again – a clearer visual demonstration of key results. | We have added a key findings section to the Discussion section in the Executive Summary.