# SEARCH STRATEGY

Database: Ovid MEDLINE(R)
1. antibiot$.mp. or exp antibiotics/
2. antimicrob$.mp.
3. exp Anti-Bacterial Agents/
4. exp Anti-Infective Agents, Urinary/
5. exp Cross Infection/
6. exp Community-Acquired Infections/
7. exp Respiratory Tract Infections/
8. exp Wound Infection/
9. exp Catheter-Related Infections/
10. exp Vancomycin Resistance/ or exp Vancomycin/ or vancomycin.mp.
11. aminoglycosides.mp. or exp Aminoglycosides/
12. fluoroquinolones.mp. or exp Fluoroquinolones/
13. broad spectrum antibiotics.mp.
14. carbapenems.mp. or exp Carbapenems/
15. exp Cephalosporins/ or broad spectrum cephalosporins.mp.
16. or/1-15
17. exp Education/ or education.mp.
18. information campaign.mp.
19. audit.mp.
20. feedback.mp. or exp Feedback/
21. dissemination.mp. or exp Information Dissemination/
22. provider reminders.mp.
23. computerized medical records.mp. or exp Medical Records Systems, Computerized/
24. exp Physician Incentive Plans/ or financial incentives.mp.
25. discharge planning.mp.
26. guideline implementation.mp.
27. guideline adherence.mp. or exp Guideline Adherence/
28. exp Quality Assurance, Health Care/ or quality assurance.mp.
29. program evaluation.mp. or exp Program Evaluation/
30. exp Practice Guideline/
31. exp Physician's Practice Patterns/
32. exp Drug Prescriptions/
33. exp Drug Utilization/
34. or/17-33
35. randomized controlled trial.mp. or exp Randomized Controlled Trial/
36. controlled clinical trial.mp. or exp Controlled Clinical Trial/
37. intervention study.mp. or exp Intervention Studies/
38. Comparative Study/
39. experiment.mp.
40. time series.mp.
41. pre-post test.mp.
42. (randomized controlled trial or controlled clinical trial).pt.
43. (randomized controlled trials or random allocation or clinical trial or double blind method or single blind method).sh.
44. exp clinical trial/
45. (clin$ adj25 trial$).ti,ab.
46. ((singl$ or doubl$ or trebl$ or trip$) adj25 (blind$ or mask$)).ti,ab.
47. (research design or placebos).sh.
48. (placebo$ or random$).ti,ab.
49. exp Double-Blind Method/
50. exp cohort studies/ or (cohort adj (study or studies)).tw. or Cohort analy$.tw. or (Follow up adj (study or studies)).tw. or (observational adj (study or studies)).tw. or Longitudinal.tw. or comparative study/ or follow-up studies/ or prospective studies/ or cohort.mp. or compared.mp. or multivariate.mp. (4148897)
51. (“time series” or pre-post or “Before and after” or intervention).tw.
52. or/35-51
53. 16 and 34 and 52
54. limit 53 to english language
55. limit 54 to humans
56. limit 55 to yr=”2000 -Current”
57. (influenza$ or antimalar$ or malaria$ or prophylax$).mp.
58. 56 not 57