# SUMMARY AND DISCUSSION

## SUMMARY OF FINDINGS BY KEY QUESTION

### Key Question #1 What is the effectiveness of inpatient antimicrobial stewardship programs on the following: a. Primary Outcome: Patient centered outcomes (30 day readmission, mortality, Clostridium difficile infection, length of stay, adverse effects) b. Secondary Outcomes: 1) Antimicrobial prescribing (timing, use, selection, dose, route, duration); 2) Microbial outcomes (institutional resistance, resistance in study population); 3) Costs (healthcare, program, opportunity, drug)?

Our systematic review of studies evaluating antimicrobial stewardship, found multiple studies that provide low level evidence that ASP programs may be associated with an improvement in antimicrobial prescribing practices and costs without negative effects on patient outcomes such as mortality, length of hospital stay, CDI, and readmissions. We caution readers in over-interpretation of findings. Despite identifying numerous studies and additional systematic reviews, the quality of the available evidence is low, prescribing improvements often not sustained, and generalizability to settings, patients or health conditions beyond those specifically studied, difficult. Few studies were randomized controlled trials. The ability to control for secular trends or other confounding variables was limited. Thus most of our findings indicate “associations” of outcomes with interventions rather than cause and effect.

Among the recent studies, the greatest body of evidence of effectiveness is for decreasing inappropriate antimicrobial use or increasing appropriate antimicrobial use, especially for prospective audit and feedback interventions. There is also some evidence of the effectiveness of audit and feedback interventions on decreasing duration of antimicrobial use. There is limited evidence of effectiveness based on antimicrobial selection or timing.

New findings included in our report are generally in agreement to conclusions from a recently updated Cochrane review that characterized interventions in a slightly different fashion.53 Although this review included 89 studies, reported findings are based on few studies with only one prescribing outcome captured per study. As noted previously, we have concerns about selective outcome reporting bias and selective analysis reporting bias in the review.

### Key Question #2 What are the key intervention components associated with effective inpatient antimicrobial stewardship (e.g., persuasive, restrictive, structural, or combination intervention; personnel mix; level of support)?

Six studies provided information on intervention components associated with effective antimicrobial stewardship. Key components identified included: consistent and persistent effort from qualified personnel, effective communication skills, support from electronic medical records or computerized decision support systems.

### Key Question #3 Does effectiveness vary by a) hospital setting (rural, urban, academic, VA, non-VA) or b) suspected patient condition?

None of the 35 studies identified in our search for recent evidence were conducted at VA medical centers. Nearly all were conducted in university-affiliated teaching hospitals. However, the recent Cochrane review included nine studies from VA hospitals noting improvement in CDI (k=2) and microbial outcomes (k=3) with mixed results for prescribing outcomes (k=3) and no change in mortality (k=1). Nine studies were conducted in ICUs and findings were similar to the overall findings.

Lung infections were the most frequently reported specific patient condition (seven studies). Results appeared qualitatively similar in these studies compared with the overall findings.

### Key Question #4 What are the harms of inpatient antimicrobial stewardship programs?

Only two studies included in this review reported possible harms associated with antimicrobial stewardship programs and both provided only anecdotal evidence. Other “harms” could include significant increases in adverse patient, microbial, or prescribing outcomes due to the ASP intervention although few studies reported these outcomes.

### Key Question #5 Within the included studies, what are the barriers to implementation, sustainability, and scalability of inpatient antimicrobial stewardship programs?

Four of the thirty-five studies identified for our review described barriers to implementation. Suggestions for improving adherence to ASPs included involvement of stakeholders and opinion leaders in guideline and program development, addition of quality improvement cycles, understanding the prescribing culture, and collaboration between physicians and pharmacists. We identified one study that addressed sustainability finding that antimicrobial costs continued to decrease over the seven years the program was in place while costs increased during the two years after program termination. A similar trend was observed for defined daily doses per 1000 patient-days. None of the studies included in our review reported on scalability.

## LIMITATIONS

We noted wide variation in populations enrolled, specific interventions utilized (even in our broad program categorization), country, hospital and unit setting and conditions and objectives assessed. There was no replication of findings from one study to another and individual studies were typically relatively small in size and short in follow-up duration. Furthermore, the studies were done in many different nations with disparate health systems, hospital organizations, staffing patterns, methods of paying for antimicrobials and for healthcare in general, formularies, systems of care, etc. Because of differences across studies and no study directly attempting to replicate previous findings we caution against inferring that any outcome variation was due to hospital setting or unit or whether effectiveness varies by suspected patient condition.

Few eligible studies were high methodological quality (randomized, controlled, double blinded trial). It would be difficult to blind investigators or participants in a trial of antimicrobial stewardship. Nearly all the studies were done in single centers and there were substantial controlled and uncontrolled influences on outcomes. The typical study was done by infectious disease pharmacists or infectious disease physicians who tried to influence antimicrobial therapy and performed formative evaluation to assess the impact of their intervention(s). Studies were often done within an existing system with available resources and measured conveniently available variables. Studies like this are more practical than large, well powered, externally funded randomized trials, but the results are also less reliable. Indeed, we are unaware of funding opportunities that are likely to support high quality, large, randomized trials of antimicrobial stewardship.

Since few studies of antimicrobial stewardship are randomized controlled trials, studies are unlikely to be entered in a registry before they are done. There is a substantial risk of reporting and publication bias—that outcomes showing a benefit of some kind are more likely to be described and studies with positive outcomes more likely to be published than studies showing no benefit or harms.

Furthermore, studies of antimicrobial stewardship with the incidence of CDI as an outcome are often initiated in response to an increase in or relatively high incidence of CDI. Many report a decrease in CDI incidence after an intervention is introduced. Unless the study is a randomized controlled trial, it is difficult to know if the decreased incidence reflects an effect of the intervention, termination of an outbreak, or regression to the mean.

Effective interventions may have been effective because of uncharacterized or unreported characteristics of the setting. These interventions may not be effective in different settings.

A number of studies present aggregate data on antimicrobial use from the entire study population rather than data on individual cases for which the intervention was applied. There are advantages associated with use of aggregate data in terms of the total hospital antimicrobial costs, but use of aggregate data does not adequately account for changes in use for cases with interventions or other defined patient groups.

## DISCUSSION

Most studies demonstrated an effect on at least one of the studied outcomes, and in nearly all these cases the effect favored the stewardship intervention. Most of the significant findings involved secondary prescribing, microbial, or cost outcomes rather than a significant change in the patient-centered outcomes we considered. Studies were not designed to adequately assess impact on mortality or other clinical outcomes. It is reassuring however, that reported improvements in prescribing and costs were not accompanied by deleterious effects on patient outcomes of mortality, length of stay, hospital readmission, and CDI. Furthermore, because a growing body of literature supports the assertion that antimicrobial use contributes to antimicrobial resistance, costs, adverse events, and other important clinical outcomes, the finding that multiple stewardship strategies can decrease antimicrobial use is encouraging. Thus evidence provided in this review suggests that there are several strategies available to clinicians that can decrease antimicrobial prescribing and limit costs, without any apparent harms.

One of the goals of stewardship is to reduce the amount of inappropriate antimicrobial use, which estimates place at 30–60% of all antimicrobial use. Only a handful of the included studies specified that the reductions in antimicrobial use came through reducing inappropriate use; possibly, some of the reductions in use involved appropriately prescribed antimicrobials. However, since most studies involved providing guidance, feedback, or opportunities to re-evaluate antimicrobial use, versus outright cessation of such use, it seems unlikely that necessary antimicrobials were discontinued at an increased rate when compared with usual clinical care. It is also possible that as use of targeted antimicrobials decreased, physicians may have used other drugs instead, a phenomenon referred to as “squeezing the balloon.”71 Future studies of antimicrobial stewardship should attempt to systematically assess changes in use of all antimicrobials, since cessation of potentially life-saving antimicrobials is one of the main hypothetical harms of antimicrobial stewardship.

Unfortunately there are few data on sustainability, scalability or specific components of interventions most likely to be effective. Suggestions for improving adherence to ASPs included involvement of stakeholders and opinion leaders in guideline and program development, addition of quality improvement cycles, understanding the prescribing culture, and collaboration between physicians and pharmacists. Studies that described ASPs noted that the composition of antimicrobial stewardship teams varied but often included a physician, pharmacist, and microbiologist. Most reviewed studies were one year or less and did not comment on sustainability. The Cochrane review found that effects were often not sustained beyond six months but with limited data on long-term effects the authors recommended future studies assess effects at one year or longer.53 None of the studies included in our review reported on scalability.

No study directly compared one intervention with another. This is unsatisfying in one sense, in that policy-makers looking for the most effective strategy for antimicrobial stewardship are left without an answer. However, the converse of this is that multiple strategies have been associated with reductions in antimicrobial use and costs, without any signal of associated harm. Accordingly, if antimicrobial stewardship is something that an organization decides to undertake, the decision as to which strategy to adopt can be tailored to fit the available resources. Given our previous concerns about the quality and applicability of data we urge that implementation be prospectively reevaluated based on ongoing evaluation of effectiveness, harms, costs and sustainability.

Although the recent Cochrane review53 included nine studies conducted in VA hospitals, we found no recent studies meeting eligibility criteria that were conducted in VA healthcare settings. One recently completed VA study that did not meet our inclusion criteria was a survey of 152 VA Medical Centers.72 Responses were received from 140 centers (response rate of 92%) and 130 of those had inpatient services. Forty-nine facilities with inpatient services (38%) reported that they had an antimicrobial stewardship team. Of those with teams, 45 of 49 (92%) had involvement of infectious disease physicians, 39 of 49 (80%) had involvement of pharmacists, and 37 of 49 (76%) had involvement of a clinical microbiology laboratory director. Fifty-five percent interfaced with the infection control committee, 31% interfaced with information technology support staff, and 29% interfaced with hospital administration. In addition, results should soon be available from a recently completed controlled before and after trial at two VA hospitals involving an audit and feedback intervention for increasing guideline concordant care for patients with catheter-associated urinary tract infection.73

Most of the published studies come from urban academic medical centers. This may reflect where the preponderance of stewardship efforts take place or, more likely, it may reflect where people involved in stewardship efforts have the resources and time to evaluate their interventions and write and submit manuscripts. As a result, it is difficult to draw conclusions about whether effectiveness varies by hospital setting.

We found substantial variability of the hospital settings of the published stewardship interventions, from entire hospitals, to specific wards, to ICUs. No article compared efforts in two or more settings. There were nine articles on interventions in ICUs and six were effective in some way. ICUs are typically smaller units with a relatively small group of prescribers, and ICUs often operate with protocols for common, high stakes conditions. Antimicrobial use is common, and often empirical. Antimicrobial resistance is common in patients in ICUs. Without precise comparative data, we are left with the impression that an intervention targeting antimicrobial use in a hospital’s ICUs might be a logical place to start and might be more likely to yield valuable results than interventions in other settings or hospital wide.

No study was designed specifically to identify harms of stewardship interventions, and few studies reported on harms. Studies not meeting eligibility criteria have reported on harms of stewardship interventions. Nicks et al. reported on a survey of emergency room physician level of understanding of the Center for Medicare and Medicaid Services (CMS) guidelines for community-acquired pneumonia.74 Many hospitals track adherence to the core measures related to the CMS guidelines. More than half of the respondents (55%; 95% CI = 47% to 70%) reported prescribing antimicrobials to patients they did not believe had pneumonia in an effort to comply with the CMS guidelines, and 42% (95% CI = 34% to 50%) of these stated that they did so more than three times per month. Only 40% (95% CI = 32% to 48%) of respondents indicated a belief that the guidelines improve patient care.

Some stewardship interventions have been perceived by providers as barriers to efficient workflow, however, we did not find high quality clinical trials documenting barriers to implementation of stewardship programs. A number of articles discussed anecdotal experience with barriers. The major types of barriers were cost of the intervention, provider resistance, and lack of adequate information systems to support stewardship efforts or evaluation of the efforts. One study that did not meet eligibility criteria reported evidence that providers alter their prescribing behavior to circumvent restrictions.75 The intervention was a requirement for prior approval of certain antimicrobial agents that was in place between 8am and 10pm. The authors observed a disproportionate number of orders for restricted drugs between 10pm and 11pm which suggested that providers wanting to order these drugs and not obtain prior approval simply waited until after the restriction was in place to order them.

## RECOMMENDATIONS FOR FUTURE RESEARCH

A typical antimicrobial course is complex, involving several decisions over hours to days or even weeks. There are many clinical, imaging, and laboratory inputs to monitor, and courses are often given to complex, heterogeneous patients. These characteristics make it difficult to conduct well-designed trials to accurately assess most outcomes.

Direct comparisons of different stewardship strategies have inherent appeal, but since there are multiple such strategies, larger comparative-effectiveness studies may need to wait until further research winnows the field down to a more manageable number of strategies for such studies. It is not easy to judge whether interventions in which authorship, review, and dissemination of guidelines occurred on a local level and/or interventions which accommodated local epidemiology were associated with better outcomes than other studies but these factors are worth consideration for future studies.

Hospitals and healthcare systems in the United States and many other countries have recognized the need for antimicrobial stewardship. The Veterans Health Administration, the Joint Committee on Accreditation, and many other organizations now expect that hospitals will take steps to increase the quality of, and diminish unnecessary, antimicrobial use. Several strategies for antimicrobial use have been proposed,49 but there is little high quality evidence on comparative effectiveness. Future research is sorely needed to clarify the benefits, potential harms, barriers, sustainability, and costs of antimicrobial stewardship programs. Generous funding for comparative effectiveness trials would be ideal. Large healthcare organizations should recognize that units within them will likely be conducting one or more stewardship activities. These organizations should strongly consider organizing these activities in a way that provides useful information on comparative effectiveness. Healthcare payers should recognize that large amounts of money will be spent on antimicrobial stewardship and that these expenditures can be more efficiently utilized if comparative research is done to identify the most effective approaches and strategies. Given that it may be hard to avoid cross-over or contamination in studies randomized at the subject level, cluster RCTs may be the most feasible way to provide high-quality evidence. Large healthcare organizations could play a role since they could provide the multiple sites—but shared data—that would make such a study feasible.

## CLINICAL CONSIDERATIONS

Until high quality comparative effectiveness research becomes available, hospitals and healthcare systems will feel pressure to do something. There is currently no definitive blueprint for how to improve antimicrobial use most effectively. However, the literature on stewardship and implementation science provides a tentative roadmap that will allow hospitals to move forward. The following reflects our synthesis of this literature.

The first step should be to use existing information or gather new information to determine where antimicrobial use might be less than ideal or is in need of improvement. Data on antimicrobial use by clinical unit, type of patients, provider groups, and by individual providers should be gathered and analyzed locally wherever possible. Usage should be compared with available national guidelines or benchmarks.76 For example, a hospital might want to analyze antimicrobial therapy for a common, important disease like community acquired pneumonia to determine how often antimicrobial therapy is consistent with guidelines,77 how often therapy is timely, how often cases with syndromes that are not likely to represent community acquired pneumonia are in fact treated as if they were, how often therapy is adjusted appropriately as clinical circumstances evolve, and how often the route and duration of therapy fit with guidelines. If there is substantial room for improvement, an intervention designed to effect that improvement would then be designed.

Hospitals and healthcare systems typically have many of the components necessary for many stewardship activities. Among these are infection prevention programs, microbiology laboratories, pharmacy services, infectious disease physicians, electronic medical record systems, continuous improvement programs, and staff or trainee education and certification programs. All of these can contribute to stewardship activities, and all should be part of planning and implementation efforts to identify areas of improvement and design strategies to improve use. It is important to inform hospital and healthcare system leaders of the need for stewardship based on local conditions and anticipated benefits and seek their support in the form of policies, procedures, and financial support.

Formative evaluation should be integral to any stewardship activity. The formative evaluation component can be built upon the information that is gathered to identify the need for the intervention in the first place. Formative evaluation will inform the participants and hospital administrators whether the program is effective. If not, the program can be strengthened, or another approach can be taken. If an intervention is effective, formative evaluation can help determine if the intervention should be continued. If a problem with antimicrobial use has been solved, it may be possible to redirect efforts and resources to solve another problem. Antimicrobial therapy is a continuously evolving area of medicine. New drugs are developed and marketed, antimicrobial susceptibilities change over time, and disease patterns change. Change and local variation are constants in antimicrobial therapy, and formative evaluation can help an organization ensure that it is ahead of the curve rather than behind it.