# REFERENCES

1 Lesprit P, Landelle C, Brun-Buisson C. Clinical impact of unsolicited post-prescription antibiotic review in surgical and medical wards: a randomized controlled trial. Clin Microbiol Infect. 2013;19:E91-7. [pmid: 23153410].
2 Camins BC, King MD, Wells JB, et al. Impact of an antimicrobial utilization program on antimicrobial use at a large teaching hospital: a randomized controlled trial. Infect Control Hosp Epidemiol. 2009;30:931-8. [pmid: 19712032].
3 Masia M, Matoses C, Padilla S, et al. Limited efficacy of a nonrestricted intervention on antimicrobial prescription of commonly used antibiotics in the hospital setting: results of a randomized controlled trial. Eur J Clin Microbiol Infect Dis. 2008;27:597-605. [pmid: 18392866].
4 Weiss CH, Moazed F, McEvoy CA, et al. Prompting physicians to address a daily checklist and process of care and clinical outcomes. Am J Respir Crit Care Med. 2011;184:680-6. [pmid: 21616996].
5 Manuel O, Burnand B, Bady P, et al. Impact of standardised review of intravenous antibiotic therapy 72 hours after prescription in two internal medicine wards. J Hosp Infect. 2010;74:326-31. [pmid: 19712997].
6 Elligsen M, Walker SAN, Pinto R, et al. Audit and feedback to reduce broad-spectrum antibiotic use among intensive care unit patients: a controlled interrupted time series analysis. Infect Control Hosp Epidemiol. 2012;33:354-61. [pmid: 22418630].
7 Standiford HC, Chan S, Tripoli M, Weekes E, Forrest GN. Antimicrobial stewardship at a large tertiary care academic medical center: cost analysis before, during, and after a 7-year program. Infect Control Hosp Epidemiol. 2012;33:338-45. [pmid: 22418628].
8 Teo J, Kwa ALH, Loh J, Chlebicki MP, Lee W. The effect of a whole-system approach in an antimicrobial stewardship programme at the Singapore General Hospital. Eur J Clin Microbiol Infect Dis. 2012;31:947-55. [pmid: 21904857].
9 Bornard L, Dellamonica J, Hyvernat H, et al. Impact of an assisted reassessment of antibiotic therapies on the quality of prescriptions in an intensive care unit. Med Mal Infect. 2011;41:480-5. [pmid: 21778026].
10 Dunn K, O’Reilly A, Silke B, Rogers T, Bergin C. Implementing a pharmacist-led sequential antimicrobial therapy strategy: a controlled before-and-after study. Int J Clin Pharm. 2011;33:208-14. [pmid: 21744190].
11 Rattanaumpawan P, Sutha P, Thamlikitkul V. Effectiveness of drug use evaluation and antibiotic authorization on patients’ clinical outcomes, antibiotic consumption, and antibiotic expenditures. Am J Infect Control. 2010;38:38-43. [pmid: 19699014].
12 Peto Z, Benko R, Matuz M, Csullog E, Molnar A, Hajdu E. Results of a local antibiotic management program on antibiotic use in a tertiary intensive care unit in Hungary. Infection. 2008;36:560-4. [pmid: 19011742].
13 Mamdani M, McNeely D, Evans G, et al. Impact of a fluoroquinolone restriction policy in an elderly population. Am J Med. 2007;120:893-900. [pmid: 17904461].
14 Aldeyab MA, Kearney MP, Scott MG, et al. An evaluation of the impact of antibiotic stewardship on reducing the use of high-risk antibiotics and its effect on the incidence of Clostridium difficile infection in hospital settings. J Antimicrob Chemother. 2012;67:2988-96. [pmid: 22899806].
15 Schnoor M, Meyer T, Suttorp N, et al. Development and evaluation of an implementation strategy for the German guideline on community-acquired pneumonia. Qual Saf Health Care. 2010;19:498-502. [pmid: 20388644].
16 Schouten JA, Hulscher MEJL, Trap-Liefers J, et al. Tailored interventions to improve antibiotic use for lower respiratory tract infections in hospitals: a cluster-randomized, controlled trial. Clin Infect Dis. 2007;44:931-41. [pmid: 17342644].
17 Fowler S, Webber A, Cooper BS, et al. Successful use of feedback to improve antibiotic prescribing and reduce clostridium difficile infection: a controlled interrupted time series. J Antimicrob Chemother. 2007;59:990-95. [pmid: 17387117].
18 Talpaert MJ, Rao GG, Cooper BS, Wade P. Impact of guidelines and enhanced antibiotic stewardship on reducing broad-spectrum antibiotic usage and its effect on incidence of Clostridium difficile infection. J Antimicrob Chemother. 2011;66:2168-74. [pmid: 21676904].
19 Goldwater SH, Milkovich G, Morrison AJ Jr, Lindgren B. Comparison of therapeutic interchange with standard educational tools for influencing fluoroquinolone prescribing. Am J Health-Syst Pharm. 2001;58:1740-5. [pmid: 11571817].
20 Meyer E, Buttler J, Schneider C, et al. Modified guidelines impact on antibiotic use and costs: duration of treatment for pneumonia in a neurosurgical ICU is reduced. J Antimicrob Chemother. 2007;59:1148-54. [pmid: 17434880].
21 Capelastegui A, Espana PP, Quintana JM, et al. Improvement of process-of-care and outcomes after implementing a guideline for the management of community-acquired pneumonia: a controlled before-and-after design study. Clin Infect Dis. 2004;39:955-63. [pmid: 15472846].
22 McGregor JC, Weeks E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13:378-84. [pmid: 16622162].
23 Barenfanger J, Short MA, Groesch AA. Improved antimicrobial interventions have benefits. J Clin Microbiol. 2001;39(8):2823-8. [pmid: 11473998].
24 Nowak MA, Nelson RE, Breidenbach JL, Thompson PA, Carson PJ. Clinical and economic outcomes of a prospective antimicrobial stewardship program. Am J Health-Syst Pharm. 2012;69:1500-8. [pmid: 22899745].
25 Carratalà J, Gardia-Vidal C, Ortega L, et al. Effect of a 3-step critical pathway to reduce duration of intravenous antibiotic therapy and length of stay in community-acquired pneumonia. Arch Intern Med. 2012;172:922-8. [pmid: 22732747].
26 Oosterheert JJ, Bonten MJM, Schneider MME, et al. Effectiveness of early switch from intravenous to oral antibiotics in severe community acquired pneumonia: multicentre randomized trial. BMJ. [doi: 10.1136/bmj.38993.560984.BE]. (published 7 November 2006).
27 Pulcini C, Dellamonica J, Bernardin G, Molinari N, Sotto A. Impact of an intervention designed to improve the documentation of the reassessment of antibiotic therapies in an intensive care unit. Med Mal Infect. 2011:546-52. [pmid: 21855239].
28 Spellberg B, Bartlett JG, Gilbert DN. The future of antibiotics and resistance. N Engl J Med. 2013;368:299-302. [pmid: 23343059].
29 Jacob JT, Gaynes RP. Emerging trends in antibiotic use in US hospitals: quality, quantification and stewardship. Expert Rev Anti Infect Ther. 2010;8:893-902. [pmid: 20695745].
30 Avorn J, Solomon DH. Cultural and economic factors that (mis)shape antibiotic use: the nonpharmacologic basis of therapeutics. Ann Intern Med. 2000;133:128-35. [pmid: 10896639].
31 Centers for Disease Control and Prevention. Get smart: know when antibiotics work. 2010. http://www.cdc.gov/getsmart/healthcare/inpatient-stewardship.html. Accessed May 17, 2013.
32 Centers for Disease Control and Prevention. Get smart: fast facts about antibiotic resistance. 2010. http://www.cdc.gov/getsmart/antibiotic-use/fast-facts.html. Accessed May 16, 2013.
33 Bartlett JG. A call to arms: the imperative for antimicrobial stewardship. Clin Infect Dis. 2011;53(S1):S4-7. [pmid: 21795727].
34 DeAngelis G, Restuccia G, Cauda R, Tacconelli E. How could we reduce antibiotic use in critically ill patients?. Infect Disord Drug Targets. 2011;11:376-83. [pmid: 21679144].
35 Blot SI, Vandewoude KH, Hoste EA, Colardyn FA. Outcome and attributable mortality in critically ill patients with bacteremia involving methicillin-susceptible and methicillin-resistant Staphylococcus aureus. Arch Intern Med. 2002;162:2229-35. [pmid: 12390067].
36 McDonald LC, Killgore GE, Thompson A, et al. An epidemic, toxin gene-variant strain of Clostridium difficile. N Engl J Med. 2005;353:2433-41. [pmid: 16322603].
37 Redelings MD, Sorvillo F, Mascola L. Increase in clostridium difficile-related mortality rates, United States, 1994–2004. Emerg Infect Dis. 2007;13:1417-19. [pmid: 18252127].
38 Gerding DN, Olson MM, Peterson LR, Teasley DG, Gebhard RL, Lee JT Jr. Clostridium difficile-associated diarrhea and colitis in adults. A prospective case-controlled epidemiologic study. Arch Intern Med. 1986;146:95-100. [pmid: 3942469].
39 Chang HT, Krezolek D, Johnson S, Parada JP, Evans CT, Gerding DN. Onset of symptoms and time to diagnosis of Clostridium difficile-associated disease following discharge from an acute care hospital. Infect Control Hosp Epidemiol. 2007;28:926-31. [pmid: 17620239].
40 Aarts M-AW, Brun-Buisson C, Cook DJ, et al. Antibiotic management of suspected nosocomial ICU-acquired infection Does prolonged empiric therapy improve outcome?. Intensive Care Med. 2007;33:1369-78. [pmid: 17558493].
41 Singh N, Rogers P, Atwood CW, Wagener MM, Yu VL. Short-course empiric antibiotic therapy for patients with pulmonary infiltrates in the intensive care unit. Am J Respir Crit Care Med. 2000;162:505-11. [pmid: 10934078].
42 Ray WA, Murray KT, Meredith S, Narasimhulu SS, Hall K, Stein CM. Oral erythromycin and the risk of sudden death from cardiac arrest. N Engl J Med. 2004;351:1089-96. [pmid: 15356306].
43 Ray WA, Murray KT, Hall K, Arbogast PG, Stein CM. Azithromycin and the risk of cardiovascular death. N Engl J Med. 2012;366:1881-90. [pmid: 22591294].
44 Shehab N, Patel PR, Srinivasan A, Budnitz DS. Emergency department visits for antibiotic-associated adverse events. Clin Infect Dis. 2008;47:735-43. [pmid: 18694344].
45 Kollef MH, Sherman G, Ward S, Fraser VJ. Inadequate antimicrobial treatment of infections. Chest. 1999;115:462-74. [pmid: 10027448].
46 Ibrahim EH, Sherman G, Ward S, Fraser VJ, Kollef MH. The influence of inadequate antimicrobial treatment of bloodstream infections on patient outcomes in the ICU setting. Chest. 2000;118:146-55. [pmid: 10893372].
47 Micek ST, Welch EC, Khan J, et al. Empiric combination antibiotic therapy is associated with improved outcomes against sepsis due to gram-negative bacteria: a retrospective analysis. Antimicrob Agents Chemother. 2010;54:1742-48. [pmid: 20160050].
48 MacDougall C, Polk RE. Antimicrobial stewardship programs in health care systems. Clin Microbiol Rev. 2005;18:638-56. [pmid: 16223951].
49 Dellit TH, Owens RC, McGowan JE Jr, Gerding DN, Weinstein RA, Burke JP. Infectious Diseases Society of America and the Society for Healthcare Epidemiology of America guidelines for developing an institutional program to enhance antimicrobial stewardship. Clin Infect Dis. 2007;44:159-77. [pmid: 17173212].
50 Ohl CA, Dodds Ashley ES. Antimicrobial stewardship programs in community hospitals: the evidence base and case studies. Clin Infect Dis. 2011;53(Suppl 1):S23-8. [pmid: 21795725].
51 Pope SD, Dellit TH, Owens RC, Hooton TM. Results of the survey on implementation of Infectious Diseases Society of America and Society for Healthcare Epidemiology of America guidelines for developing an institutional program to enhance antimicrobial stewardship. Infect Control Hosp Epidemiol. 2009;30:97-98. [pmid: 19046053].
52 Fishman N. Antimicrobial stewardship. Am J Med. 2006;119(6A):S53-S61. [pmid: 16735152].
53 Davey P, Brown E, Charani E, et al. Interventions to improve antibiotic prescribing practices for hospital inpatients. Cochrane Database of Systematic Reviews. 2013;(4). Art. No.: CD003543. [doi: 10.1002/14651858.CD003543.pub3].
54 Davey P, Brown E, Fenelon L, et al. Interventions to improve antibiotic prescribing practices for hospital inpatients. Cochrane Database of Systematic Reviews. 2005;4. Art. No.: CD003543. [doi: 10.1002/14651858.CD003543.pub2].
55 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
56 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions – Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2010;63:513-23. [pmid: 19595577].
57 Cairns KA, Jenney AWJ, Abbott IJ, et al. Prescribing trends before and after implementation of an antimicrobial stewardship program. Med J Aust. 2013;198:262-6. [pmid: 23496402].
58 Liebowitz LD, Blunt MC. Modification in prescribing practices for third-generation cephalosporins and ciprofloxacin is associated with a reduction in meticillin-resistant Staphylococcus aureus bacteraemia rate. J Hosp Infect. 2008;69:328-36. [pmid: 18602189].
59 Magedanz L, Silliprandi EM, dos Santos RP. Impact of the pharmacist on a multidisciplinary team in an antimicrobial stewardship program: a quasi-experimental study. Int J Clin Pharm. 2012;34:290-4. [pmid: 22382886].
60 Yeo CL, Chan DSG, Earnest A, Wu TS, Yeoh SF, Lim R, et al. Prospective audit and feedback on antibiotic prescription in an adult hematology-oncology unit in Singapore. Eur J Clin Microbiol Infect Dis. 2012;31:583-90. [pmid: 21845470].
61 Lewis GJ, Fang X, Gooch M, Cook PP. Decreased resistance of Pseudomonas aeruginosa with restriction of ciprofloxacin in a large teaching hospital’s intensive care and intermediate care units. Infect Control Hosp Epidemiol. 2012;33:368-73. [pmid: 22418632].
62 Mangino JE, Peyrani P, Ford KD, et al. Development and implementation of a performance improvement project in adult intensive care units: overview of the Improving Medicine Through Pathway Assessment of Critical Therapy in Hospital-Acquired Pneumonia (IMPACT-HAP) study. Crit Care. 2011;15:R38. [pmid: 21266065].
63 Yong MK, Buising KL, Cheng AC, Thursky KA. Improved susceptibility of Gram-negative bacteria in an intensive care unit following implementation of a computerized antibiotic decision support system. J Antimicrob Chemother. 2010;65:1062-69. [pmid: 20215130].
64 Goldstein EJC, Citron DM, Peraino V, Elgourt T, Meibohm AR, Lu S. Introduction of ertapenem into a hospital formulary: effect on antimicrobial usage and improved in vitro susceptibility of Pseudomonas aeruginosa. Antimicrob Agents Chemother. 2009;53:5122-6. [pmid: 19786596].
65 Schuetz P, Miller B, Christ-Crain M, Stoltz D, Tamm M, Bouadma L. Procalcitonin to initiate or discontinue antibiotics in acute respiratory tract diseases. Cochrane Database of Systematic Reviews. 2012;9. Art. No.: CD007498. [doi: 10.1002/14651858.CD007498.pub2].
66 Agarwal R, Schwartz DN. Procalcitonin to guide duration of antimicrobial therapy in intensive care units: a systematic review. Clin Infect Dis. 2011;53(4):379-87. [pmid: 21810753].
67 Jensen J, Hein L, Lundgren B, et al. for the Procalcitonin And Survival Study (PASS) Group. Procalcitonin-guided interventions against infections to increase early appropriate antibiotics and improve survival in the intensive care unit: a randomized trial. Crit Care Med. 2011;39:2048-58. [pmid: 21572328].
68 Annane D, Maxime V, Faller JP, et al. Procalcitonin levels to guide antibiotic therapy in adults with non-microbiologically proven apparent severe sepsis: a randomized controlled trial. BMJ Open. 2013;3:e002186.
69 Weiss CH, Persell SD, Wunderink RG, Baker DW. Empiric antibiotic, mechanical ventilation, and central venous catheter duration as potential factors mediating the effect of a checklist prompting intervention on mortality: an exploratory analysis. BMC Health Serv Res. 2012;12:198. [pmid: 22794349].
70 Schouten JA, Hulscher MEJL, Natsch S, Kullberg B-J, van der Meer JWM, Grol RPTM. Barriers to optimal antibiotic use for community-acquired pneumonia at hospitals: a qualitative study. Qual Saf Health Care. 2007;16:143-9. [pmid: 17403764].
71 Burke JP. Antibiotic resistance--squeezing the balloon?. JAMA. 1998;280(14):1270-1. [pmid: 9786379].
72 Roselle GA, Neuhauser M, Kelly A, Vandenberg P. 2012 Survey of antimicrobial stewardship in VA. Washington, DC. Department of Veterans Affairs. May. 2013.
73 Trautner BW, Kelly PA, Petersen N, et al. A hospital-site controlled intervention using audit and feedback to implement guidelines concerning inappropriate treatment of catheter-associated asymptomatic bacteriuria. Implement Sci. 2011;6:41. [pmid: 21513539].
74 Nicks BA, Manthey DE, Fitch MT. The Centers for Medicare and Medicaid Services (CMS) community-acquired pneumonia core measures lead to unnecessary antibiotic administration by emergency physicians. Acad Emerg Med. 2009;16:184-7. [pmid: 19133854].
75 LaRosa LA, Fishman NO, Lautenbach E, Koppel RJ, Morales KH, Linkin DR. Evaluation of antimicrobial therapy orders circumventing an antimicrobial stewardship program: investigating the strategy of “stealth dosing”. Infect Control Hosp Epidemiol. 2007;28:551-6. [pmid: 17464914].
76 Huttner B, Jones M, Rubin MA, et al. Double trouble: how big is a problem is redundant anaerobic antibiotic coverage in Veterans Affairs medical centers?. J Antimicrob Chemother. 2012;67:1537-39. [pmid: 22398652].
77 Mandell LA, Wunderink RG, Anzueto A, Bartlett JG, Campbell GD, Dean NC. Infectious disease society of America/American thoracic society consensus guidelines on the management of community-acquired pneumonia in adults. Clin Infect Dis. 2007;44(Suppl 2):S27-72. [pmid: 17278083].