# METHODS

## TOPIC DEVELOPMENT

Our key questions were developed with input from a technical expert panel.

The final key questions are:

Key Question #1 What is the effectiveness of inpatient antimicrobial stewardship programs on the following:
  a. Primary Outcome: Patient centered outcomes (30 day readmission, mortality, Clostridium difficile infection, length of stay, adverse effects)
  b. Secondary Outcomes: 1) Antimicrobial prescribing (timing, use, selection, dose, route, duration); 2) Microbial outcomes (institutional resistance, resistance in study population); 3) Costs (healthcare, program, opportunity, drug)?
Key Question #2 What are the key intervention components associated with effective inpatient antimicrobial stewardship (e.g., persuasive, restrictive, structural, or combination intervention; personnel mix; level of support)?
Key Question #3 Does effectiveness vary by a) hospital setting (rural, urban, academic, VA, non-VA) or b) suspected patient condition?
Key Question #4 What are the harms of inpatient antimicrobial stewardship programs?
Key Question #5 Within the included studies, what are the barriers to implementation, sustainability, and scalability of inpatient antimicrobial stewardship programs?

## SEARCH STRATEGY

An exploratory search identified a 2005 Cochrane review that partially addressed the key questions but was no longer current (search dates 1980 to 2003).54 We used a search strategy similar to that of the Cochrane review to search MEDLINE (Ovid) through June 2013. We limited the search to studies published from 2000 to the present, in English language, and enrolling human subjects. Our search included terms for antimicrobial agents (e.g., anti-bacterial agents, anti-infective agents), infection types, and program implementation (e.g., guideline implementation, practice patterns). The full search strategy is presented in Appendix A. Additional citations were identified from systematic reviews, reference lists of retrieved articles, and suggestions made by our technical expert panel members.

## STUDY SELECTION

Titles, abstracts, and articles were reviewed by investigators and research associates trained in the critical analysis of literature. During title and abstract review, we excluded studies for the following reasons and identified for full text review any articles that either did not fall into one of these categories or there was uncertainty about eligibility:

1. Study not published in English language,
2. Study done in nursing home (long-term care) setting. Studies were included if done in a mix of hospital or outpatient and nursing home settings if results were presented separately by site,
3. Study not about antimicrobial stewardship,
4. Study of antimicrobials for medical or surgical prophylaxis,
5. Study of patients with viral or fungal infection or tuberculosis,
6. Pediatric study EXCEPT randomized, controlled trials in pediatric settings,
7. Study not involving an intervention or not involving an intervention of interest; we excluded interventions that were exclusively provider education (i.e., interventions designed exclusively for enhancing knowledge such as seminars, memos, grand rounds); patient education programs were included; community/public health campaigns were excluded,
8. Description of an intervention with no assessment of the effect of the intervention,
9. Survey of hospitals to establish range of measures used to control or optimize antibiotic prescribing,
10. Study design OTHER THAN randomized, controlled trial, controlled clinical trial, controlled before/after study, or interrupted time series with at least 3 time points before and after implementation of the intervention,
11. No outcomes of interest; outcomes of interest are a) Clinical (e.g., morbidity, mortality, length of stay), b) Drug (e.g., decision to prescribe, appropriateness of selection, dose, route, etc.), Micro (Microbiological – colonization), Cost, Other (process, sustainability, scalability etc.).

We reviewed full text versions of potentially eligible articles and excluded studies that met any of the criteria outlined in items 1 to 11 above. We also added the following exclusion criterion: study done in setting not relevant to medicine in the United States or involving a population or infectious disease not relevant to United States population.

With the recent update of the Cochrane review,53 we excluded from our review any studies published in the updated version.

## DATA ABSTRACTION

From studies identified as eligible after full-text review we extracted the following:

1. Study characteristics – region, intervention, intervention staff (to develop and implement the intervention), resources (i.e., hardware or software used or purchased, staff hired), study design, hospital type, site within hospital (e.g., surgical unit, medical unit, ICU), patients enrolled (number, age), suspected site of infection, suspected organism. We typically categorized ASP interventions using original study author classification. However, we reviewed these classifications with our internal content experts and our Technical Expert Panel Members and stakeholders to ensure general agreement. Within each category we assessed and reportedly separately on specific types of interventions.
2. Patient outcomes – 30-day readmission, mortality, C. difficile infection, length of stay, morbidity, adverse effects
3. Antimicrobial prescribing outcomes – timing, use, selection, dose, route, duration
4. Microbial outcomes – institutional resistance and resistance in the study population
5. Costs – healthcare, program, opportunity, drug
6. Harms of stewardship program implementation
7. Other – barriers to implementation, sustainability and scalability of intervention.

From each study, we extracted all data fitting the descriptions of the outcomes in the list above including multiple outcomes, if provided. Our evidence tables (see Appendix), summary tables, and summaries of the evidence report the specific outcome data.

For ITS studies, we report, where provided by study authors, level and trend (or slope) results. Level refers to the change in the value of the outcome measure from pre- to post-intervention. Trend refers to the change between the slope of the line through data points before the intervention and the line through data points after the intervention.

## QUALITY ASSESSMENT

We assessed the risk of bias of individual studies using the criteria developed for use in Cochrane Effective Practice and Organization of Care (EPOC) reviews (Appendix B). There are nine criteria for assessing risk of bias for studies with a separate control group (i.e., RCTs, CCTs, and CBA studies) and seven criteria for assessing risk of bias for ITS studies. Each element is scored as high, unclear, or low risk. A study was rated as low risk of bias if each of the individual criteria were scored as low risk, medium risk of bias if one or two criteria were scored as unclear or high risk, and high risk of bias if more than two criteria were scored as unclear or high risk.

Quality of systematic reviews was determined using the measurement tool for assessment of multiple systematic reviews (AMSTAR).55

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included studies, organized by intervention category. We critically analyzed studies to compare their characteristics, methods, and findings. We created forest plots for outcomes with sufficient data to calculate risk ratios. However, due to heterogeneity of interventions, study designs, patient populations, and outcomes reporting among studies for an intervention, the results cannot be meaningfully pooled. Therefore, we compiled a summary of findings for each key question and drew conclusions based on qualitative synthesis of the findings.

## RATING THE BODY OF EVIDENCE

We rated overall strength of evidence for our patient outcomes for each intervention category using methods developed by AHRQ and the Effective Health Care Program.56 The strength of the evidence was evaluated based on four domains: 1) risk of bias (whether the studies for a given outcome or comparison have good internal validity); 2) consistency (the degree of similarity in the effect sizes, i.e., same direction of effect, of the included studies); 3) directness (reflecting a single, direct link between the intervention of interest and the outcome); and 4) precision (degree of certainty surrounding an effect estimate of a given outcome).

## PEER REVIEW

A draft version of this report was reviewed by technical experts as well as clinical leadership. Reviewer comments and our responses are presented in Appendix C.