# INTRODUCTION

It is estimated that in 2009, more than 3 million kilograms of antimicrobials were administered to human patients in the United States.28 While the life-saving benefits of antimicrobials are indisputable, the consequences of use and misuse must also be considered.29 Unlike any other medication, antimicrobial use influences not only the patient being treated but also the surrounding ecosystem.30,31 Major concerns related to the use of antimicrobials are increasing microbial resistance, higher incidence of antimicrobial associated Clostridium difficile (C. difficile) infection (CDI), other drug related toxicities and increased healthcare costs.29

Over the past decade, the number of bacteria identified as resistant to antimicrobials has increased and commonly prescribed antimicrobial treatments are becoming ineffective.32 A major factor in the emergence of drug-resistant bacteria is bacterial evolution with selective pressure applied via antimicrobial usage including the choice of antimicrobial therapy, the duration of therapy, the route of administration, and the dosage.33,34 At the patient level, treatment with an antimicrobial increases the risk that the patient will become colonized or infected with a resistant organism.31,34 At the hospital level, increased use of antimicrobials has increased the prevalence of resistant bacteria in hospitals.31 Infections due to resistant pathogens, including the epidemic strain of C. difficile and Methicillin-resistant Staphylococcus aureus (MRSA), are associated with increases in morbidity and mortality.35–37

Historically, as new resistance patterns emerged, antimicrobial agents with new targets or new mechanisms of action were developed and became available for use. That approach has slowed dramatically largely due to economic and regulatory factors.28 Among the suggestions for addressing this delay in the “antibiotic pipeline” are new approaches to funding research and development and a modification of the drug approval process to allow clinical superiority trials.28

CDI is concentrated in hospitals and chronic care facilities. The pathogen is widespread in a hospital environment, elderly populations are most vulnerable, and there is high use of fluoroquinolones in those facilities conferring a selective advantage, particularly to the epidemic strain of C. difficile.33,36 Eighty-five percent or more of patients with C. difficile associated disease were exposed to antimicrobials in the 28 days before infection.38,39

Costs associated with antimicrobial use include not only drug costs but costs associated with adverse events and costs associated with antimicrobial resistance.30 Several studies have reported over-prescription of antimicrobials in intensive care units (ICUs). Longer courses without clear evidence of infection or courses extending beyond usual durations have no benefits for patients in infectious disease outcomes but substantial harms including increased length of stay, increased adverse effects, and possibly increased mortality when comparing patients treated for 3 or 4 days to those treated for as long as 20 days.40,41 Increased mortality, increased length of hospital stay, and lost productivity must also be considered.29 Additionally, an increased risk of death from cardiovascular causes has been reported in patients taking erythromycin42 or azithromycin.43 Of emergency department visits for drug-related adverse events, over 19% were due to antimicrobial use with allergic reactions most common.44

Inappropriate use of antimicrobials includes prescription of antimicrobials when they are not needed, continuation of antimicrobials when they are no longer needed, prescription of the wrong dose, use of broad-spectrum agents for bacteria susceptible to narrow-spectrum agents, and choice of wrong antimicrobials for an infection.31 Prescribing decisions made by less-experienced staff members (i.e., interns and residents), pressure to decrease hospital length of stay, and increasingly complex clinical presentation are all potential factors in inappropriate prescribing.30

While much of the emphasis is on overuse of antimicrobials, there is evidence of increased mortality associated with inadequate antimicrobial therapy.45–47 Therefore, in an effort to optimize the use of antimicrobial agents in hospitalized settings, antimicrobial stewardship programs have been created.

## ANTIMICROBIAL STEWARDSHIP PROGRAMS

An antimicrobial stewardship program (ASP) is a focused effort by a healthcare organization or a portion of an organization (i.e., an intensive care unit) to optimize antimicrobial use for the purposes of improving patient outcomes, reducing adverse consequences (toxicity, selection of pathogenic organisms, or emergence of resistance), and delivering cost-effective therapy.29,48–50 The emphasis is on appropriate selection, dosing, route, and duration of antimicrobial therapy.49,50 Despite recognition of the growing problem of antimicrobial resistance, a 2008 survey estimated that only 48% of hospitals in the US had an antimicrobial stewardship program in place.51

Proposed strategies for improving antimicrobial stewardship typically involve prospective audit and feedback, formulary restriction, pre-authorization of prescriptions, guidelines for prescribing and/or modifying therapy, and education.49,52 A comprehensive ASP may include some or all of the following:30,49,52

- a multidisciplinary team consisting of infectious disease physicians, clinical pharmacists, clinical microbiologists, information system specialists, infection control specialists, and hospital epidemiologists
- collaboration between the ASP team and hospital infection control and pharmacy and therapeutics committees
- support and collaboration of hospital administrators, medical staff leadership, and local providers
- hospital administrative support for computer systems and other resources to improve decision making, measure and track antimicrobial use, track resistance patterns, and identify hospital-based infections and adverse drug events,
- a microbiology laboratory to provide patient-specific data for optimizing treatment, surveillance of resistant organisms, and molecular-level investigation of outbreaks.

## PURPOSE AND SCOPE OF REVIEW

The purpose of this review is to synthesize the evidence about the effectiveness of antimicrobial stewardship programs implemented in hospital settings. The report was nominated by Matthew Goetz, MD, Chief, Infectious Diseases, VA Greater Los Angeles Healthcare System, on behalf of the VA Antimicrobial Stewardship Task Force, and is intended to provide a summary of the evidence on inpatient antimicrobial stewardship programs to guide clinical practice and policy within the Veterans Healthcare System. We focus on adult hospital inpatients and limit our review to randomized controlled trials (RCTs), controlled clinical trials (CCTs), controlled before and after studies (CBAs), and interrupted time series (ITS) analyses with data for at least 3 time points before and after the intervention. Our main outcomes of interest were patient-centered outcomes. We also report prescribing outcomes, microbial outcomes, costs, harms of stewardship programs, key intervention components, and barriers to implementation, sustainability, and scalability. In particular, as described above, improvements in antimicrobial prescribing and microbial outcomes and costs can be considered meaningful at a patient, hospital and ecosystem level. Therefore, evidence demonstrating a neutral or lack of untoward effect on clinical outcomes may be sufficient for practice policy implementation. We summarize the findings from a prior Cochrane review that included studies published through 2009^53^ and focus on studies published since the time of that review.