# EVIDENCE TABLES

Table 1 Audit and Feedback Interventions: Study Characteristics

Table 2 Audit and Feedback Interventions: Site, Patient, and Infection Characteristics

Table 3 Audit and Feedback Interventions: Clinical/Patient Outcomes

Table 4 Audit and Feedback Interventions: Prescribing Outcomes

Table 5 Audit and Feedback Interventions: Microbial Outcomes

Table 6 Audit and Feedback Interventions: Cost and Harms Outcomes

Table 7 Audit and Feedback Interventions: Risk of Bias Assessment for RCT, CCT, and CBA Studies

Table 8 Audit and Feedback Interventions: Risk of Bias Assessment for ITS Studies

Table 9 Formulary Restriction and Preauthorization Interventions: Study Characteristics

Table 10 Formulary Restriction and Preauthorization Interventions: Site, Patient, and Infection Characteristics

Table 11 Formulary Restriction and Preauthorization Interventions: Clinical/Patient Outcomes

Table 12 Formulary Restriction and Preauthorization Interventions: Prescribing Outcomes

Table 13 Formulary Restriction and Preauthorization Interventions: Microbial Outcomes

Table 14 Formulary Restriction and Preauthorization Interventions: Cost and Harms Outcomes

Table 15 Formulary Restriction and Preauthorization Interventions: Risk of Bias Assessment for RCT, CCT, and CBA Studies

Table 16 Formulary Restriction and Preauthorization Interventions: Risk of Bias Assessment for ITS Studies

Table 17 Guidelines with Feedback Studies: Study Characteristics

Table 18 Guidelines with Feedback Studies: Site, Patient, and Infection Characteristics

Table 19 Guidelines with Feedback Studies: Clinical/Patient Outcomes

Table 20 Guidelines with Feedback Studies: Prescribing Outcomes

Table 21 Guidelines with Feedback Studies: Risk of Bias Assessment for RCT, CCT, and CBA Studies

Table 22 Guidelines with Feedback Studies: Risk of Bias Assessment for ITS Studies

Table 23 Guidelines without Feedback Studies: Study Characteristics

Table 24 Guidelines without Feedback Studies: Site, Patient, and Infection Characteristics

Table 25 Guidelines without Feedback Studies: Clinical/Patient Outcomes

Table 26 Guidelines without Feedback Studies: Prescribing Outcomes

Table 27 Guidelines without Feedback Studies: Microbial Outcomes

Table 28 Guidelines without Feedback Studies: Cost and Harms Outcomes

Table 29 Guidelines without Feedback Studies: Risk of Bias Assessment for RCT, CCT, and CBA Studies

Table 30 Guidelines without Feedback Studies: Risk of Bias Assessment for ITS Studies

Table 31 Computerized Decision Support Studies: Study Characteristics

Table 32 Computerized Decision Support Studies: Site, Patient, and Infection Characteristics

Table 33 Computerized Decision Support Studies: Clinical/Patient Outcomes

Table 34 Computerized Decision Support Studies: Prescribing Outcomes

Table 35 Computerized Decision Support Studies: Microbial Outcomes

Table 36 Computerized Decision Support Studies: Cost and Harms Outcomes

Table 37 Computerized Decision Support Studies: Risk of Bias Assessment for RCT, CCT, and CBA Studies

Table 38 Computerized Decision Support Studies: Risk of Bias Assessment for ITS Studies

Table 39 Protocol Studies: Study Characteristics

Table 40 Protocol Studies: Site, Patient, and Infection Characteristics

Table 41 Protocol Studies: Clinical/Patient Outcomes

Table 42 Protocol Studies: Prescribing Outcomes

Table 43 Protocol Studies: Microbial Outcomes

Table 44 Protocols Studies: Risk of Bias Assessment for RCT, CCT, and CBA Studies

Table 45 Protocol Studies: Risk of Bias Assessment for ITS Studies