# PEER REVIEW COMMENTS/AUTHOR RESPONSES

REVIEWER COMMENT | RESPONSE
1. Are the objectives, scope, and methods for this review clearly described?
Yes | Thank you
Yes. I think the questions asked are very clear and are the correct ones to be asking for this issue | Thank you
No. Objectives: I assume that the objectives refer to the five “Key Questions” that were posed as there are no “Objectives” The Key Questions posed are clear. The Scope of the synthesis and the definition of which studies constitute “Antibiotic Stewardship” interventions are problematic. The authors cite the standard definition for Antimicrobial Stewardship Programs (ASP) and the context for the synthesis is developed from that perspective, rather than the broader perspective of “ Antibiotic Stewardship provider targeted intervention to improve antibiotic prescribing in hospitals”. This is important because many clinician directed interventions to improve antibiotic prescribing have not been conducted in the formal context of ASP or “ Prospective Audit and Feedback” or “Formulary Restriction”. Many of the endpoints of these additional published studies have included many of the same endpoints of interest posed in the Key Questions for this synthesis. | Thank you We recognize that there are many observational studies and reports of implementation of stewardship programs at individual hospitals or within a health care system. The gold standard for evidence of effectiveness, however, is a controlled trial, preferably randomized. We did broaden our search to include controlled before and after studies and interrupted time series. Given that we did find numerous trials of these designs, we did not find it necessary to expand our search further to include observational studies.
The authors cite a recent Cochrane Systematic review that reviews the evidence in support of Antibiotic Stewardship from the perspective or “persuasive” versus “restrictive” interventions ( analogous to Prospective audit w feedback and formulary restriction). The Cochrane review is well done and extensive, yet the authors of the ESP synthesis fail to sufficiently integrate evidence from the Cochrane analysis; limiting the current analysis to a relatively narrow focus. The types of studies (RCT, ITS, etc.) included for review in the current synthesis are appropriate. | We have expanded our reporting of findings from the Cochrane review and have attempted to integrate their findings with our findings.
Methods: The search strategy (Appendix A) is acceptable and the authors clearly state that there intent is to focus on literature published since 2000 because of the Cochrane analysis; however the study selection process for inclusion is not transparent and needs further description. The criteria utilized to select studies (pg 17) were reasonable, but it is not clear which “persuasive” interventions (#2) were excluded (pg 19, n=127 articles excluded) and why. A key component of Audit and Feedback approach to ASP involves education. | Methods: We excluded studies of interventions that were exclusively education. If education was part of the audit and feedback or guideline intervention, the study was included. Audit and feedback, guidelines with feedback, and guideline without feedback most closely fit with the Cochrane category of “persuasive” interventions.
Pg 19. Literature flow. Not very clear how criteria were used to exclude articles at the abstract level. Please explain. | We have added information on abstract and full text review to the Study Selection section.
Were reviewers blinded to author when reviewing studies/abstracts? Was there an algorithm for excluding full text articles ( based on exclusion criteria) that might be included as an appendices? | Reviewers were not blinded to author. We had a list of exclusion criteria (see Study Selection section) and an abstract or article was excluded if it met any of the criteria.
It is unclear to me why the Cochrane review utilizing very similar definitions and quality assessments includes 89 studies including 52 studies conducted in the U.S.(8 within the VA) yet this systematic review includes 29 studies, virtually none of which were in the 2013 Cochrane. Some of the VA studies in the Cochrane analysis are frequently cited in the literature regarding ASP. Please explain and justify the discrepancy. | We have deleted from our report any references cited in the 2013 Cochrane Review. The Cochrane review includes studies published from 1980 to 2006 (EMBASE) or 2009 (EPOC Register). It includes studies in pediatric settings and studies of prophylactic antimicrobials – two areas we chose to exclude. None of the studies from our search were done in VA hospitals. We have added a summary of the VA studies cited in the Cochrane review.
It would be illuminating to include an appendix with excluded full text articles that were reviewed, (+/−) the major reason for exclusion. | We are aware that some reviews include a list of excluded studies but we have chosen not to do so
Quality assessment: No issues. Didn’t see quality assessments of Structured reviews. Did I miss them? Data Synthesis: Perhaps if a larger number of studies were included for each Key Question there would be less heterogeneity and it might be possible to perform meta-analyses on select outcomes? | Quality assessment: We rated the quality of the reviews using the AMSTAR criteria but had failed to note that for the Davey 2013 review. All three reviews now have a quality rating assigned.
Pg 19 Indicates that 29 studies and 3 systematic reviews were included in the “synthesis”, yet the description of the Cochrane results is limited to a ½ page with the findings limited to 3 sentences. In this reviewers opinion, this in unacceptable given findings in the Cochrane meta-regression, meta-analyses indicating a larger effect size for restrictive interventions on secondary outcomes antibiotic use/ inappropriate prescribing and Clostridium difficile rates, as well as reductions in pneumonia mortality with improved prescribing. (see comments in item 4) Rating body of evidence: No Issues | As noted above, we have expanded our reporting of findings from the Cochrane review. Interestingly, the meta-analyses for clinical outcomes in the Cochrane review are based on small subsets of the 89 included studies (i.e., 3, 4, 5, 6, and 11 studies).
Yes
Yes. The main objective for this review that needs to be more clearly stated is how exactly it serves as a complement to the recently published Cochrane review on interventions to improve antibiotic prescribing practices for hospital inpatients. Is the objective of this review to serve as a systematic review that only focuses on studies published since 2000 (i.e. a “more modern, 21st century” version of what was done in the Cochrane review) or was it to review studies that were left out of the Cochrane review (which only reviewed studies to 2006)? There are actually two studies included in this review (Fine 2003, Micek 2004) that were also included in the Cochrane review; I would recommend leaving these out of this review if the purpose is to only update what was done in the Cochrane review. However, I think it is fine for the purpose of this review to be a “more modern 21st century” version of what was done in the Cochrane review, but I would take care to include otherwise eligible studies that might have been disqualified solely because they appear in the Cochrane review (I cannot tell if this has been done) | Our original intention was to update the 2009 Cochrane review which was based on studies published to 2003. However, we also wanted to base our report on the categorization of interventions as described by Dellit (2007). Subsequently, the 2013 Cochrane review was published. We chose to keep our original search dates and include studies that met our eligibility criteria. We have now modified our review to remove any study included in the Cochrane review and we have attempted to better integrate their findings with our findings. However, as per currently accepted AHRQ-EPC methods we have not formally pooled results from the Cochrane review into our report. Instead we devote a separate section to the Cochrane review and provide some additional summary of all results in the discussion.
Yes. The statement of the questions and scope seem reasonable. The methods are fairly clear overall, but the application of the methods could perhaps be clearer. There are some problems, I think, with how well this uniquely supports the conclusions it makes. The 2013 Davey study covers much of the same ground—though only through to 2013. It might be useful to highlight those studies that are incorporated here that are not in the Davey study. Also, although I agree in general with the conclusions of this manuscript, I think that for the purposes of VA, it might be useful to consider a broader range of studies. | The Cochrane review (Davey 2013) literature search dates are 1980 to 2006 (in EMBASE). The EPOC Register was searched in 2007 and 2009. We identified 30 studies published after 2006. We are unclear as to what “broader range of studies” should be included. We focused our report on adult inpatient settings that met minimal criteria for reducing risk of bias outcomes.
The objectives and scope are clear. However, the methodology (e.g., exclusion criteria for studies included in the evidence based synthesis, data points included in summary tables) could be expanded for more clear comprehension. | We have made some changes to the Study Selection and Data Abstraction sections to make this information clearer.
2. Is there any indication of bias in our synthesis of the evidence?
No
No
Yes. No bias indicated regarding quality assessments of included studies or ratings for the body of evidence. However, these are dependent upon the studies that are included in the synthesis. Inclusion of additional studies or further elaboration on the Cochrane findings may impact rating the body of evidence, particularly the effects on antibiotic use, antibiotic resistance, and CDI. | As noted above, consistent with prior AHRQ-EPC methods we have rated the quality and strength of evidence separately for studies we identified and reviewed and specifically noted this as an extension of the Cochrane review. We have revised considerably the section describing the updated Cochrane review and excluded any studies reported there to minimize overlap and confusion to readers.
While likely not intentional this reviewer perceived a slight bias relative to pharmacy related interventions based on a comment that physician recommendations were accepted at a higher rate than pharmacists (which was a finding of the paper reviewed), however the Cochrane review included a number of pharmacy directed /authored manuscripts, and other studies have shown that inclusion of pharmacists in ASP result in improved appropriate prescribing and reduced CDI rates. PMID 11438891, PMID 23719885. The document should be reviewed from that context for bias, and future ESP of Antibiotic Stewardship topics should include at least consultation with an ID pharmacist in addition to physicians. | The statement about physician vs. pharmacist recommendations was inaccurate in the draft report. We have corrected that statement. We have reviewed the suggested references: PMID 11438891 Gross 2001: not eligible for inclusion (a case-control study which was also excluded from the Cochrane review) PMID 23719885 Cappelletty 2013: not eligible for inclusion (before and after study) Several of our Stakeholders and Technical Expert Panel members were ID pharmacists.
No
No
No
No
3. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Yes. I am puzzled by the exclusion of several studies: These studies seem to meet the criteria for study selection in that per my perusal they did not meet the exclusion criteria listed on page 8 and were not included in the previous Cochrane Review. All studies were published prior to December 2012 and thus I believe would have been captured by the literature review. | Thank you for the suggested references. We have reviewed them for possible inclusion.
1. Cosgrove SE et al. Evaluation of postprescription review and feedback as a method of promoting rational antimicrobial use: a multicenter intervention. Infect Control Hosp Epidemiol. 2012 Apr;33(4):374–80. doi: 10.1086/664771.; 2. Lesprit P, Landelle C, Girou E, Brun-Buisson C. Reassessment of intravenous antibiotic therapy using a reminder or direct counselling. J Antimicrob Chemother. 2010 Apr;65(4):789–95. doi: 10.1093/jac/dkq018.; 3. Elligsen M, Walker SA, Pinto R, Simor A, Mubareka S, Rachlis A, Allen V, Daneman N. Audit and feedback to reduce broad-spectrum antibiotic use among intensive care unit patients: a controlled interrupted time series analysis. Infect Control Hosp Epidemiol. 2012 Apr;33(4):354–61. doi: 10.1086/664757.; 4. Bornard L, et al. Impact of an assisted reassessment of antibiotic therapies on the quality of prescriptions in an intensive care unit. Med Mal Infect. 2011 Sep;41(9):480–5. doi: 10.1016/j.medmal.2010.12.022.; 5. Jenkins TC et al. Decreased Antibiotic Utilization After Implementation of a Guideline for Inpatient Cellulitis and Cutaneous Abscess. Arch Intern Med. 2011;171(12):1072–1079.; 6. Arnold FW et al. Improving antimicrobial use in the hospital setting by providing usage feedback to prescribing physicians. Infec Control Hosp Epidemiol. 2006; 27:378–382. | 1. Cosgrove 2012: Not eligible for inclusion (before and after study); 2. Lesprit 2010: Not eligible for inclusion (before and after study); 3. Elligsen 2012: Added to review (audit and feedback); 4. Bornard 2011: Added to review (audit and feedback); 5. Jenkins 2011: Not eligible for inclusion (before and after study); 6. Arnold 2006: Not eligible for inclusion (before and after study)
The following articles are relevant but while epublished in 2012 the print versions are from 2013 and thus may be out of scope; 1. Lesprit P, Landelle C, Brun-Buisson C. Clinical impact of unsolicited post-prescription antibiotic review in surgical and medical wards: a randomized controlled trial. Clin Microbiol Infect. 2013 Feb;19(2):E91–7. doi: 10.1111/1469-0691.12062. Epub 2012 Nov 15.; 2. Lesprit P, Landelle C, Brun-Buisson C. Unsolicited post-prescription antibiotic review in surgical and medical wards: factors associated with counselling and physicians’ compliance. Eur J Clin Microbiol Infect Dis. 2013 Feb;32(2):227–35. doi: 10.1007/ s10096-012-1734-3. Epub 2012 Aug 24. | We updated our literature search date to June 2013. The first Lesprit study cited has been added to our review (audit and feedback). The second study was not eligible because it is not one of our included study designs.
It would be useful to have a table of 217 articles excluded because of study design exclusions | When we review studies, we do not keep track of all of the reasons a study may be ineligible. Therefore studies excluded for other reasons may also have been ineligible because of study design.
Nguyen et al. J Antimicrob Chemother 2008;61;714 Lewis et al. Infect Control Hosp Epidemiol 2012;33:368 Cappelletty et al. Evaluating the impact of a pharmacist’s absence from an AST. Am J Health-sys pharm. 2013;70:1065 (may not meet inclusion criteria but useful information on what happens when ASP is taken away) Pellerin et al. Infect control Hosp Epidemiol 2012;33:432 Leander et al. Infect control Hosp Epidemiol 2012;33:434 Apisarnthanarak A. et al. Clin Infect Dis. 2006;42(6):768–75. Valiquette L, Cossette B, Garant MP, Diab H, Pepin J. Clin Infect Dis 2007;45(20):S112–S121. Rattanaumpawan. J Antimicrob Chemother 2011; 66: 2655–2658 Kaki et al. J Antimicrob Chemother 2011; 66: 2655–2658 (systematic review of ASP in ICU) Liew et al. Eur J Clin Microbiol Infect Dis (2011) 30:853–855 Stano et al. In vivo 2012;26(3)469. Diazgranados et al. American Journal of Infection Control. 40(6):526–9, 2012 Aug Cairns et al. Medical Journal of Australia. 198(5):262–6, 2013 Mar 18. Wong et al. Annals of Pharmacotherapy. 46(11):1484–90, 2012 Nov Aldeyab et al. Journal of Antimicrobial Chemotherapy. 67(12):2988–96, 2012 Dec Niwa et al. International Journal of Clinical Practice. 66(10):999–1008, 2012 Oct. Nowak et al. American Journal of Health-System Pharmacy. 69(17):1500–8, 2012 Sep 1 Yam et al. American Journal of Health-System Pharmacy. 69(13):1142–8, 2012 Jul 1 Liew et al. Int J Antimicrobial Agents 2012;40:55 Advic et al. Clin Infect Dis 2012;54:1581 Teo et al. Eur J clin Micro Infect Dis 2012;31:947 Beardsley et al. Infect control Hosp Epidemiol 2012;33:398 Cosgrove et al. Infect Control Hosp Epidemiol 2012;33:374 Talpaert et al. J Antimic Chemother 2011;66:2168 Enoch et al. QJM 2011:104:411 Lima et al. Brazilian J Infect Dis 2011;15:1 Cheng et al. Eur J Clin Micro Infect Dis 2009;28:1447 Goldstein et al. Antimic Agents Chemother 2009;53:5122 Wong-Beringer et al. Pharmacotherapy 2009;29:736 | Thank you for the suggestions. We have reviewed each of the suggested studies for possible inclusion We have included the following studies: Lewis 2012 (formulary restriction and preauthorization) Cairns 2013 (audit and feedback) Aldeyab 2012 (formulary restriction and preauthorization) Nowak 2012 (computerized decision support) Teo 2012 (audit and feedback) Talpaert 2011 (guidelines with feedback) Goldstein 2009 (protocol studies) The following studies were not eligible: Nguyen 2008 (case control study) Cappelletty 2013 (before and after study) Pellerin 2012 (letter) Leander 2012 (before and after study) Apisarnthanarak 2006 (before and after study) Valiquette 2007 (response to an outbreak rather than stewardship) Rattanaumpawan 2011 (case control study) Kaki 2011 (systematic review – we had already looked at this review for possible references missed in our search) Liew 2011 (case series) Stano 2012 (not effect of an intervention) Diazgranados 2012 (before and after study) Wong 2012 (before and after study) Niwa 2012 (before and after study) Yam 2012 (before and after study) Liew 2012 (looks at accepted versus rejected recommendations rather than effect of intervention) Advic 2012 (before and after study) Beardsley 2012 (before and after study) Cosgrove 2012 (before and after study) Enoch 2011 (observational study) Lima 2011 (before and after study) Cheng 2009 (before and after study) Wong-Beringer 2009 (before and after study)
Yes. See item 4 regarding Cochrane | See response in item #4.
No
Yes. I found a few studies that were not included that may meet criteria for inclusion: Audit and feedback studies:; 1. Elligsen M, Walker SA, Pinto R, Simor A, Mubareka S, Rachlis A, Allen V, Daneman N. Audit and feedback to reduce broad-spectrum antibiotic use among intensive care unit patients: a controlled interrupted time series analysis. Infect Control Hosp Epidemiol 2012;33(4):354–61.; 2. Solomon DH, Van Houten L, Glynn RJ, Baden L, Curtis K, Schrager H, Avorn J. Academic detailing to improve use of broad-spectrum antibiotics at an academic medical center. Arch Int Med 2001;161:1897–1902.; Formulary restriction and pre-authorization; 1. Lewis GJ, Fang X, Gooch M, Cook PP. Decreased resistance of Pseudomonas aeruginosa with restriction of ciprofloxacin in a large teaching hospital’s intensive care and intermediate care units. Infect Control Hosp Epidemiol 2012;33(4):368–73; Protocol:; 1. Carratala J, Garcia-Vidal C, Ortega L, Fernandez-Sabe N, Clemente M, Albero G, Lopez M, Castellsague X, Dorca J, Verdaguer R, Martinez-Montauti J, Manresa F, Gudiol F. Effect of a 3-step critical pathway to reduce duration of intravenous antibiotic therapy and length of stay in community-acquired pneumonia. Arch Int Med 2012;172(12):922–8.; 2. Singh N, Rogers P, Atwood CW, Wagener MM, Yu VL. Short-course empiric antibiotic therapy for patients with pulmonary infiltrates in the intensive care unit. Am J Respir Crit Care Med 2000;162:505–11. | Thank you for the suggested references. We have reviewed each of the studies for possible inclusion. Audit and feedback; 1. Elligsen 2012: added; 2. Solomon 2001: included in Cochrane review; Formulary restriction; 1. Lewis 2012: added; Protocol; 1. Carratala 2012: added; 2. Singh 2000: included in Cochrane review
As I related above, I think that there are other studies. The following PMID relates a time-series study 16465632. Other studies may be worthy of mention that were supported by the CDC epicenters. Although the quality of these other studies leave much to be desired, I wonder whether they might be important. | Thank you for the suggested reference. This study (Madaras-Kelly 2006) is included in the Cochrane review.
Refer to my colleagues’ comments regarding concern of Cochrane review and others studies that should be considered for inclusion. | See responses above.
4. Please write any additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
I fully accept that the intent of this report is to not duplicate the previous Cochrane review on this topic. However, I believe that it is quite important to put the findings of this review into the proper context, the Cochrane review providing that context. As it now stands, the only meaningful assessment of the findings of the Cochrane review appear on page 20; this discussion provides the types of outcomes assessed in the Cochrane review but provides only a terse summary regarding what the impact of various stewardship interventions was on some of the outcomes evaluated in the Cochrane analysis; note that no mention is made of the microbial outcomes (colonization or infection with C. difficile or antimicrobial-resistant bacteria) considered in the Cochrane analysis. In contrast there is a good discussion of what the Cochrane review on laboratory (pro-Calcitonin) testing on pages 66–67. This model should be used for a presentation of the Cochrane findings on the impact of inpatients antimicrobial stewardship programs. | We have added more information from the Cochrane and how our findings are similar or dissimilar.
I recommend that the discussion clearly indicate that the intermediary mechanism by which antimicrobial stewardship leads to changes in clinical, microbiological and economic outcomes is through changes in antimicrobial utilization. There needs to be more emphasis on the degree to which the various interventions achieved this intermediary endpoint. Inherently interventions that do not change usage are unlikely to change outcomes. For interventions that do change utilization, there are many uncertainties as to what types of changes most affect the outcomes (e.g,, length of therapy, breadth of therapy, or change in use of certain drug classes [e.g. fluoroquinolones vs. broad-spectrum beta-lactams). It is probably worth stating that few or no studies are sufficiently well powered to or even attempt to answer such granular questions. MAJOR POINTS | We agree and provided additional emphasis on that throughout the document. In particular we have noted that positive changes in prescribing, microbial and cost outcomes may be sufficient to affect clinical practice policy if there is sufficient evidence that they do not result in untoward effects on clinical outcomes. Because most studies were not specifically designed to assess clinical outcomes addressing this issue is somewhat more difficult-though we believe we have addressed as robustly as the data allow. We have also added information to the discussion.
- The Cochrane review categorized studies as being Persuasive interventions, restrictive interventions and structural interventions. To facilitate comparison of the results of ESP and Cochrane reviews it would be useful to clearly state how the various categories investigated in the ESP review (Audit and Feedback, etc.) correlate with these Cochrane categories | As noted above, we have attempted to integrate the findings from the Cochrane review with our findings (including how our intervention categories mesh with the Cochrane categories)
- It is important to emphasize the lack of harms of stewardship programs. | We have added that results suggest that clinical outcomes were not adversely affected. There are little specific data on harms so that the data do not allow us to “emphasize the lack of harms.”
- Tables 2–11, 13: The titles of these tables should be changed to Strength of Evidence for Guidelines without Feedback Studies, by CLINICAL Outcome as no data are provided regarding microbiological, prescribing or economic outcomes. The exclusion of tabular presentation of these other outcomes increases the difficulty in quickly assessing the study-to-study findings in these important realms. | We have made this change. We pre-specified that patient outcomes were our primary outcome and therefore chose to evaluate strength of evidence for the clinical outcomes. We have created separate overview tables for clinical and prescribing outcomes.
- page 47, table 9, Capelastegui 2004: The outcome, mortality is presented as “Reduced, OR 1.8 [1.1, 2.9]”. This is very confusing. I expect that the study presented the OR for death before the intervention vs. after the intervention; if so the OR should be inverted so that the data presentation is more logical. | Pg 47 Capelastegiu: This is a controlled before/after study. The reported OR was for the control hospital cohort post-intervention with the intervention hospital as the reference so that an OR>1.0 indicates lower mortality at the intervention hospital. We have added a footnote to the table.
- page 47, table 9, Meyer 2007: The outcome, mortality is presented as “Reduced, p<0.05”. In contrast the text on page 46 states: “The ITS aimed at reducing duration of treatment reported an increased number of deaths in the ICU after the intervention (6.9% vs. 4.1%, p<0.001).(Meyer 2007) “. Similar the text on page 65, 3rd full paragraph: text states “An ITS study enrolling patients with CAP found significantly higher mortality following guideline implementation.(Meyer 2007)”. The inconsistency between the text and the table should be resolved. Note that Table 14 also shows the mortality as having increased after the intervention in the Meyer 2007 study. | Pg 47 Meyer: Thank you. We have corrected this. Mortality increased after the intervention in this study.
- page 62, last paragraph: the text indicates says that the Barenfanger 2001 demonstrated that “Lower mortality, shorter lengths of stay, and cost savings were noted for the intervention group”. In contras the text on page 11 states that “mortality did not differ significantly (10% in the control group, 11% in the study group, p=0.074) and table 11 reports the RR for mortality in the Barenfanger study as being 1.12 (0.62, 2.01). | Pg 62 Baranganger – Thank you. We have corrected this. This study included several analyses and our reporting is now consistent.
- page 70, harms of therapy: It seems inconsistent with the data driven presentation throughout the rest of the document to report that authors “speculated that two patients may have had antimicrobials stopped unnecessarily. When the antimicrobials were subsequently restarted, the patients improved.(Yeo 2012) “Without any quantitative analysis this borders on the anecdotal and would seem to have no place in the presentation. If retained, there would need to be a tabular presentation of the totality of findings across all studies. | Pg 70 We have emphasized that these are anecdotal findings. While we agree that presenting data would be ideal they are not provided. We believe that including this information is preferable to excluding.
MINOR POINTS Page 1. Please change my title Page 2, line 3. Indicate the date of the literature used in the prior Cochrane review. Page 3. RESULTS section: reverse the order of these two sentences “We also summarize three systematic reviews that were relevant to this topic. Eight were RCTs, four were CCTs, four were CBA studies, and thirteen ITS studies.” Page 4: Formulary Restrictions and… Add “AMS” (last sentence) to list of abbreviations Page 13: 4th paragraph, line 6. Insert “of” between the phrase “increased risk death…” Page 33: 3rd text paragraph, 1st line; insert “in” into the phrase “..conducted a University hospital…”. Page 40, table 7, last row: The outcome is incidence of CDI while the strength of evidence, by outcome is “Low for readmission”. This should be corrected. Page 72:3rd full paragraph: Change “infectious control program” to “infection control program” Page 75, last paragraph: Pulcini 2011 is cited but the reference does not appear in the reference list | MINOR POINTS Thank you for your careful read of our draft report. Pg 1. We have made this change. Pg 2. We have added literature search dates. Pg. 3. We have made this change. Pg 4. We have replaced AMS with ASP throughout. Pg 13. We have made this change Pg 33. This paragraph has been modified and the correction has been made. Pg 40. We have made this correction. Pg 72. We have made this change. Pg 75. Pulcini 2011 has been added to the reference list.
First let me say that it is obvious how much work this report was and we appreciate it immensely. Although the Cochrane Group just released an updated review on this same topic, it only included studies up until 2006 and as I could tell from this review, there have been many studies published since. Some of my suggestions are small details and others relate to the overall report | Thank you.
1. Probably my biggest concern regarding this report is that it only includes information published AFTER the Cochrane analysis. While I understand the reason for this and there should not be a need to redo that analysis, it makes it appear that this is all the relevant literature there is, which is misleading unless someone had thoroughly read the Cochrane analysis. Although there is a very small paragraph in the introduction about that analysis, it doesn’t do justice to the volume of literature published prior to this report. In fact, the Cochrane analysis found that in those 89 studies found that antimicrobial prescribing was reduced 35–42%, that ASP’s decreased Clostridium difficile infections (CDI) by 68%, decreased resistance in gram-negative bacteria by 25%, gram-positive resistance by 10% and improved mortality by interventions aimed to improve prescribing in CAP. I think it would be important to include that data either as a summary table in the introduction or divided through the report under the areas that are being reviewed in the current report. (a nice example is listed on page 60 where the Cochrane PCT review is discussed) | 1. As noted above, we have added more information (including summary tables) from the Cochrane review and we have attempted to integrate the Cochrane findings and our findings. It is worth noting that although the review included 89 studies, many of the outcomes are based on far fewer studies. The observed reduction in prescribing was based on 76 studies and the median changes ranged from 3.5% to 42.3%. However, the reported decrease in CDI was based on 5 studies, gram-negative bacteria on 9 studies, gram-positive bacteria on 7 studies, and mortality in CAP patients on 4 studies
2. I found the current version extremely difficult to read. The text was dense and covered in details, and the tables, while very useful, were really busy. Would it be possible to have the evidence summaries made much more visible and useful, so that busy people could avoid the majority of the text and just read the summaries? I’d also love to see Forest plots as these are very useful to get information quickly and visually from a prolonged document. Again – adding the prior studies to a forest plot from the Cochrane analysis would be a way to combine / incorporate the data and be VERY useful. The audit and feedback section, in particular, was almost impossible to read and retain any useful information. | 2. We have put the prescribing outcomes on a separate table from the clinical outcomes. We have also placed summaries by outcome at the start of the sections about each of the interventions. We have created forest plots for mortality and appropriate prescribing. Due to the use of effect sizes in the Cochrane review, we did not feel it was appropriate to add to their plots.
3. I appreciate the attempt to break the sections by type of intervention, but as many studies (and existing ASP programs) look at multiple ways to improve antimicrobial use, I wonder if it wouldn’t be more effective to divide by OUTCOME first (i.e. clinical, microbial, use, cost), and then break out by type of intervention. I think that would be easier to read and more clinically useful, and there might be less overall repetition of studies in the text. | 3. We appreciate the suggestion but have decided to leave sections organized by intervention. We recognize that many interventions are multifaceted and we have attempted to clarify studies that used multifaceted interventions throughout the report.
4. In tables, in addition to RR and CI, I always find raw numbers useful, as that gives a more realistic understanding of the actual effect. This might fit in Executive summary table 2 or in the Appendix tables (include the results from each along with study characteristics). Sometimes it’s very useful to be able to quickly review that for a specific study. | 4. The Appendix tables provide raw numbers where reported. Many studies merely commented that findings were not significantly different. We thought adding to the summary tables would make the table more “busy.”
5. In the introduction, nothing is mentioned about the dwindling antibiotic pipeline and why this is a crisis now. The Cochrane analysis has a really nice statement about that in their introduction – maybe something similar could be mentioned. | 5. We have added this to the introduction.
6. Executive summary table 1 – I feel the wording “no improvement in mortality” is misleading. In general, these types of interventions are not expected to reduce mortality, and as stated in the text are more balancing outcomes. More useful to say “no difference was seen” I love executive summary table 2 – lots of good information in a small space. | 6. We agree and have modified the statements on Exec Summary Table 1 to focus on differences as you suggested.
7. Mention is made several times that there were “no VA studies”. There are many wonderful examples of studies from the VA in the Cochrane analysis. It just sounds bad to say the VA hasn’t participated in this. | 7. As noted above, we have added a summary of the VA studies cited in the Cochrane review and mention a VA study from which results are expected soon.
8. Figure 1 – I’d like more information about the 217 studies that were excluded as “not included study design”. Why were they excluded and do any of those provide useful details that cannot be obtained from the referenced studies? | 8. As noted above, when we review studies, we do not keep track of all of the reasons a study may be ineligible. Therefore studies excluded for other reasons may also have been ineligible because of study design. A listing, therefore, would not be accurate. We pre-specified our inclusion criteria for study designs with approval from our Technical Expert Panel.
9. Page 24 – under audit and feedback, CDI should be listed under microbial outcomes, not clinical outcomes. The headings and bullet points are very useful. Maybe outlining this section will make it more pop more so people are drawn to the summaries. For the other key findings sections, these headings weren’t used. Is there a reason they aren’t consistent? | 9. Because “screening asymptomatic individuals for C. difficile colonization is rare almost all individuals diagnosed with CDI have clinical signs and symptoms. Therefore, we believe that this is most appropriately classified as a clinical outcome. We have added headings and bullet points to each intervention category.
10. Tables 2,4,6,8,10,12 are really useful | 10. Thank you.
11. I still find table 1 really busy. This is the meat of the entire report and should be the most helpful piece. I still think it would be more effective to have the outcomes on the left column (use, cost, prescribing, microbial) and have the types of interventions on subsequent columns. | 11. We have split the table into two tables – one for clinical outcomes and one for prescribing outcomes – to make the table more reader-friendly.
12. The strength of evidence tables are useful and well done | 12. Thank you.
13. Again, the lack of inclusion of prior studies make some activities look like there isn’t much data. Formulary restriction and preauthorization, for example, was one of the first ASP initiatives done and was well studied in the 1970’s – late 1990s. As a result, very few people feel the need to replicate this very large body of data. Some type of summary of the existing data would give perspective. | 13. We recognize this limitation and have attempted to incorporate findings from the Cochrane report (with literature search dates from 1980 to 2006) in our review.
14. For key questions #2, 3, 4 and 5 – there is no summary of the final results. | 14. Summaries have been added.
15. I found tables 14 and 15 very helpful, especially if someone is trying to look at ICU specifically or respiratory tract infections | 15. Thank you.
16. The summary and discussion at the end was extremely well written and brings in many of the additional points support ASP even considering the weakness of the current evidence. Again, I think when you look at the total body of work for ASP it is much more impressive than the current review suggests, although admittedly most of the studies are weak in design. | 16. Thank you. As noted, we have attempted to include more information from the Cochrane review in our review.
17. References – Fine 2003 and Pulchini 2011 aren’t listed in the references. Schouten 2007 – there are two references listed and the tables don’t address which one is being referred to. | 17. Fine 2003 has been deleted (already in Cochrane review), Pulcini has been added, and we have noted the correct Schouten reference in the text.
18. The evidence tables in Appendix D are excellent. I think they would be further enhanced by including results, including the actual outcomes (% mortality, incidence of CDI and MDRO, and actual costs avoided or usage changes) | 18. Thank you. We reported information as provided by authors which often didn’t include actual outcome data.
There are two approaches that can be taken to improve the synthesis. The first approach would be to dedicate a section for each Key Question and incorporate the findings of the prior systematic reviews, perhaps adding sections to relevant tables. The second approach would be to expand the definition of studies to include more studies that were identified in the Cochrane analysis, and include the relevant studies directly in this synthesis. The quality of the studies included in the Cochrane analysis has already been determined using similar assessments of quality. In either approach full synthesis should include both studies reviewed as well as findings from other “syntheses”. | We have attempted to integrate the findings from the Cochrane review into our review so that our review provides an update
Because the data are not formally analyzed, the heterogeneous nature of the studies, and description of individual study findings seem to meld together. While the authors do a reasonable job of summarizing the findings at the end of the paper, the text could be improved substantially by integration of the findings at the end of each outcomes section and Key Question. Currently, this is inconsistent from section to section. | We have standardized the reporting format for each intervention section (Key Question #1) and added summary points for each key question.
I was on the TEP of this report and was therefore able to provide feedback and recommendations throughout the process. I appreciated how responsive the authors were to feedback. They have produced a very nice and thorough overview of this complicated topic. The main drawback of this report is that the studies done on this topic are not of very high quality. This is not something that the authors can change. However, they do an excellent job of highlighting this limitation. I do wonder if they should also comment on how a disruptive innovation is necessary to tackle this problem – perhaps, the focus should be away from ASP and toward appropriate diagnosis. But, overall, an outstanding job. | Thank you. Given the length of the report and likely speculation regarding this point we have elected not to further comment.
Page 3, 3rd paragraph and page 14, last paragraph: Add “VA Greater Los Angeles Healthcare System” after “Chief, Infectious Diseases” and delete “Program” from “Antimicrobial Stewardship Task Force.” | Pg 3. Thank you. We have made these changes.
Page 4: Audit and Feedback section: Would recommend inserting a brief definition of what the authors considered to represent “audit and feedback” and how it is distinguished from “preauthorization.” For example, the Rattanaumpawan 2010 study fell under “preauthorization” even though the “drug use evaluation” done in the study was done up to 3 days following the prescription being written. | Pg 4. We have clarified that we considered studies to be “audit and feedback” if feedback on an individual patient basis was provided within 24 hours of the review and was provided directly to the prescriber (either written or verbally). The Rattanaumpawan study includes elements of audit and feedback and we have clarified throughout the report which studies were multifaceted.
Page 6: Executive Summary Table 1 (and page 22, Table 1): Would report microbial outcomes in a similar format to how prescribing outcomes are reported (i.e. “+” for positive relationship, “≈” for no clear relationship, “−” for negative relationship). For example, under “Prospective Audit and Feedback” Microbial Outcomes, would say “mixed outcome ≈ 1 study; decrease in MRSA ≈ 2 studies.” | Pg. 6.
Page 13, 9th line up from bottom: Insert “of” between “risk” and “death.” | Pg 13. Thank you. We have made this change.
Page 20, “Existing Systematic Review” section: I would include a more in-depth discussion of the existing Cochrane review and define exactly how this current review is different. I’d delineate how the Cochrane review approaches the topic primarily by distinguishing restrictive versus persuasive interventions, while this review focus more on format of intervention (i.e. audit-feedback vs. formulary restriction vs. guidelines vs. CDS vs. protocol). It might be worth mentioning that the Cochrane review did find significant reduction in mortality for interventions intended to increase effective prescribing for pneumonia; I might break down the studies examined in that section according to our intervention formats. | Pg 20. We have added information about the Cochrane review (included studies, characterization of studies, outcomes) and clarified how the current review is different.
Page 33, 3rd line of the 1st paragraph under “Characteristics of Studies”: Add “two were” between “and” and “ITS.” | Pg 33. Thank you. With the addition of 2 studies, this paragraph has been modified.
Page 33, 2nd paragraph under “Characteristics of Studies”: Explain why Rattanaumpawan study was included under formulary restriction and not audit and feedback (see above). | Pg 33. As noted above, we have added more information about multifaceted studies.
Page 55: last paragraph, 1st line: add “6” to “Oosterheert 200” | Pg 55. Thank you. References have been converted to superscript format.
Page 55, last paragraph, 6th line: Would recommend breaking up sentence by putting period before “however.” | Pg 55. Thank you. To make the document more readable, many of the study details have been eliminated from the text and appear only on the Appendix tables.
Page 75: first paragraph, 1st line: Delete “that” prior to “low” | Pg 75. Thank you. We have made this change.
Page 84: References: Please add the Pulcini 2011 study (included in the Protocol section) to the references | Pg 84. Thank you, the reference has been added.
If my comments are off target then please ignore, but I am concerned that the conclusions of the synthesis are difficult and non-specific. There is more information in the literature that might be more helpful, albeit the studies are of low quality. The structure and policies that represent our best guesses for stewardship should be discussed. | We have attempted to clarify and refine the conclusions. We have reviewed other potentially eligible studies and included them if they met criteria. We have discussed the structures and policies whereby evidence may guide in stewardship implementation and have suggested areas for future research and evaluation of implemented programs; the latter is a particularly critical need given the low quality of existing data and the limited applicability to other settings.
Table 1 (page 23): It is challenging to quickly understand framework for data included in outcome columns. The reader may be misled with + and ≈ symbols. | We have created separate tables for clinical and prescribing outcomes to clarify the reporting.
5. Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
A fuller synthesis of the results of this analysis (supplemented by apparently missing articles as identified previously) with the results of prior Cochrane reviews would be quite useful. | We have added more information from the Cochrane review and have attempted to integrate their findings with our findings.
Please try to decrease the text and increase the use of Forest plots or graphs as described above | We have attempted to decrease the text. We have added forest plots for mortality and appropriate prescribing – the two outcomes where authors reported, or we were able to calculate, risk ratios.
A modification of the framework for a more user friendly version is much needed for stewardship implementers to read and comprehend these data. The repetition of studies in the text and tables should be streamlined. | We have attempted to create more reader-friendly tables and we have attempted to streamline the text and avoid duplication.