# SUMMARY AND DISCUSSION

We identified six good-quality SRs that evaluated thromboprophylaxis using newer oral anticoagulants versus LMWH. One SR evaluated additional drug classes, including unfractionated heparin, aspirin, and vitamin K antagonists. Although we identified no direct comparisons of newer oral anticoagulants, two good-quality SRs indirectly compared one newer oral anticoagulant with another through common comparison to enoxaparin.21,23 Only one SR compared combined pharmacologic and mechanical thromboprophylaxis to either method alone.9 FXa inhibitors have been studied more extensively than DTIs. In the absence of head-to-head comparisons between newer oral anticoagulants, it is difficult to draw strong conclusions on inter- or intra-drug class differences. The main findings and strength of evidence from our literature synthesis are summarized by key question in the section that follows.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### KQ 1 Newer Oral Anticoagulants Versus Standard Treatments

FXa inhibitors. Rivaroxaban and apixaban are the most commonly studied FXa inhibitors. The risk of symptomatic DVT was reduced with FXa inhibitors thromboprophylaxis compared with LMWH, while the risk of nonfatal PE and mortality was not significantly different (all high strength of evidence). The estimated absolute risk difference was 4 fewer symptomatic DVT events for each 1000 patients receiving thromboprophylaxis with FXa inhibitors over 5 weeks compared with LMWH. However, these benefits were offset by an increase in major bleeding (moderate strength of evidence). The absolute risk difference was 2 more major bleeding events per 1000 patients on FXa thromboprophylaxis over a period of 5 weeks. Higher doses of FXa inhibitors but not intermediate or low doses were associated with increased major bleeding.20 Subgroup analysis by specific drug and type of surgery showed a reduced risk of bleeding with apixaban compared with LMWH in TKR but not in THR; risk of major bleeding with rivaroxaban did not differ significantly for either surgery.35 No reviews identified trials comparing oral FXa inhibitors with warfarin, UFH, or oral antiplatelet agents.

Direct thrombin inhibitors. Dabigatran is the only FDA-approved oral DTI, and the only DTI evaluated in existing SRs. Compared with LMWH, dabigatran was not associated with significant differences for any outcome examined. The strength of evidence was low for most outcomes due to few events and imprecise estimates of effect; also, effects on mortality varied substantially across studies. In addition to the major outcomes, a subgroup analysis in one SR found no significant difference between both treatment groups on bleeding requiring rehospitalization.9 No reviews identified trials comparing oral DTIs with warfarin, unfractionated heparin, or oral antiplatelet agents.

Table 7 summarizes the findings and strength of evidence for the effects of newer oral anticoagulant drug classes compared with enoxaparin in patients undergoing THR or TKR surgery.

Table 7 Summary of the strength of evidence for KQ 1

Outcome | Domains Pertaining to SOE | | | | Effect Estimate (95% CI) | SOE
Outcome | Number of Studies (Subjects) | Study Design/Quality | Consistency Directness | Precision Publication Bias | Effect Estimate (95% CI) | SOE
FXa vs. LMWH^a^
Mortality (up to 10 weeks) | 11 (22,838) | RCT/Good | Consistent Direct | Precise None detected | OR=0.95 (0.55 to 1.63) RD=0 (2 fewer to 1 more) deaths/1000 patients | High
Symptomatic DVT (up to 5 weeks) | 18 (22,877) | RCT/Good | Consistent Direct | Precise None detected | OR=0.46 (0.30 to 0.70) RD=4 fewer (3 to 6 fewer) events/1000 patients | High
Nonfatal PE (up to 5 weeks) | 20 (26,998) | RCT/Good | Consistent Direct | Precise None detected | OR=1.07 (0.65 to 1.73) RD=0 (1 fewer to 2 more) events/1000 patients | High
Major bleeding (up to 5 weeks) | 21 (31,424) | RCT/Good | Inconsistent Direct | Precise None detected | OR=1.27 (0.98 to 1.65) RD=2 more (0 to 4 more) events/1000 patients | Moderate
LMWH vs. DTI^b^
Mortality (up to 13 weeks) | 4 (10,080) | RCT/Good | Inconsistent Direct | Imprecise None detected | TKR RR=1.06 (0.36 to 3.12) RD=0 (2 fewer to 6 more) events/1000 patients THR RR=1.17 (0.04 to 36.52) RD=0 (3 fewer to 107 more) events/1000 patients | Low
Symptomatic DVT (up to 5 weeks) | 4 (10,264) | RCT/Good | Consistent Direct | Imprecise None detected | RR=0.82 (0.17 to 3.99) RD=2 fewer (7 fewer to 27 more) events/1000 patients | Low
Symptomatic PE (up to 5 weeks) | 4 (10,264) | RCT/Good | Consistent Direct | Imprecise None detected | OR=0.69 (0.31 to 1.54) RD=1 fewer (2 fewer to 2 more) events/1000 patients | Low
Major bleeding (up to 5 weeks) | 4 (10,264) | RCT/Good | Consistent Direct | Imprecise None detected | RR=0.94 (0.58 to 1.52) RD=0 (3 fewer to 3 more) events/1000 patients | Moderate
FXa or DTI vs. other antithrombotics
All outcomes | 0 | NA | NA | NA | Not estimable | Insufficient

a Data from Neumann, 2012.

b Risk ratio data from Ringerike, 2012, and Gómez-Outes, 2012; risk difference calculated; SOE ratings from Sobieraj, 2012.

Notes: Outcomes are short-term; there may be some differences for hip versus knee replacement (different baseline risk and different duration of anticoagulation in existing studies); there is some evidence that FXa inhibitors at higher doses increase risk of bleeding.

Abbreviations: CI=confidence interval; DVT=deep vein thrombosis; DTI=direct thrombin inhibitor; FXa=factor X inhibitor; LMWH=low molecular weight heparin; NA=not applicable; OR=odds ratio; PE=pulmonary embolism; RCT=randomized controlled trial; RD=risk difference; RR=risk ratio; SOE=strength of evidence; THR=total hip replacement; TKR=total knee replacement

### KQ 2 Combined Pharmacological and Mechanical Prophylaxis

No reviews identified trials comparing newer oral anticoagulants combined with mechanical prophylaxis to pharmacological prophylaxis alone. Even when considering standard treatments, very little data are available comparing combined-modality thromboprophylaxis and pharmacologic prophylaxis only. One SR found moderate strength of evidence that combined-modality thromboprophylaxis was associated with a decreased risk of overall DVT (including asymptomatic events) compared with pharmacologic prophylaxis only.9 The evidence was insufficient for all other outcomes.

### KQ 3 Comparisons of Individual Newer Oral Anticoagulants

Only indirect comparisons of rivaroxaban, apixaban, and dabigatran were performed through common comparison with LMWH.23,35 These comparisons were made for only two of our major outcomes—symptomatic VTE (DVT or PE) and major bleeding. There were no significant differences in treatment effect for symptomatic VTE or major bleeding. Because these indirect comparisons are subject to confounding and the treatment effects were imprecise, we considered the strength of evidence low. Other outcomes reported included clinically relevant bleeding and net clinical endpoints. Rivaroxaban was found to be associated with an increased risk of clinically relevant bleeding, but there was no significant difference in net clinical endpoints (symptomatic VTE, major bleeding and death). Table 8 summarizes the findings and strength of evidence for between-drug comparisons of newer oral anticoagulants in patients undergoing THR or TKR.

Table 8 Summary of the strength of evidence for KQ 3

Outcome | Domains Pertaining to SOE | | | | Effect Estimate (95% CI) | SOE
Outcome | | | | | Effect Estimate (95% CI) | SOE
Outcome | Number of Studies (Subjects) | Study Design/Quality | Consistency Directness | Precision Publication Bias | Effect Estimate (95% CI) | SOE
Apixaban, rivaroxaban, dabigatran^a^
Mortality | NR | NA | NA | NA | Outcome not reported | Insufficient
Symptomatic DVT | NR | NA | NA | NA | Outcome not reported | Insufficient
Nonfatal PE | NR | NA | NA | NA | Outcome not reported | Insufficient
Symptomatic VTE | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | Rivaroxaban vs. dabigatran | Low
Symptomatic VTE | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | RR=0.68 (0.21 to 2.23)
Symptomatic VTE | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | RD=3 fewer (11 fewer to 4 more) events/1000 patients
Symptomatic VTE | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | Rivaroxaban vs. apixaban | Low
Symptomatic VTE | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | RR=0.59 (0.26 to 1.33)
Symptomatic VTE | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | RD=4 fewer (9 fewer to 1 more)/1000 patients
Symptomatic VTE | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | Apixaban vs. dabigatran | Low
Symptomatic VTE | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | RR=1.16 (0.31 to 4.28)
Symptomatic VTE | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | RD=1 more (7 fewer to 8 more)/1000 patients
Major bleeding | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | Rivaroxaban vs. dabigatran | Low
Major bleeding | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | RR=1.37 (0.21 to 2.23);
Major bleeding | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | RD=4 more (2 fewer to 11 more) events/1000 patients
Major bleeding | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | Rivaroxaban vs. apixaban | Low
Major bleeding | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | RR=1.59 (0.84 to 3.02);
Major bleeding | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | RD=5 more (2 fewer to 12 more)/1000 patients
Major bleeding | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | Apixaban vs. dabigatran | Low
Major bleeding | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | RR=1.16 (0.31 to 4.28);
Major bleeding | 16 (38,747) | RCT/Good | NA Indirect | Imprecise None detected | RD=0 (8 fewer to 7 more)/1000 patients

a Data from Gómez-Outes, 2012.

Abbreviations: DVT=deep vein thrombosis; NA=not applicable; NR=not reported; PE=pulmonary embolism; RD=risk difference; RR=risk ratio; SOE=strength of evidence; VTE=venous thromboembolism

## CLINICAL AND POLICY IMPLICATIONS

Patients undergoing total knee replacement or total hip replacement are at a significant risk for VTE. The precise risk for VTE in contemporary orthopedic surgery is difficult to estimate because of changes in surgical management, the paucity of recent trials comparing thromboprophylaxis to placebo, and the high frequency of thromboprophylaxis in routine practice, making observational studies of natural history difficult to conduct. A recent, careful analysis estimated the prevalence of symptomatic VTE without thromboprophylaxis at 2.8 percent for the initial 14 days and 4.3 percent at 35 days following major orthopedic surgery.1 Appropriate use of perioperative thromboprophylaxis significantly reduces the risk of postoperative proximal VTE, but the evidence is much more limited for effects on symptomatic DVT, PE, and mortality.1,9

Our evidence synthesis primarily addresses the comparative effectiveness of newer oral anticoagulants compared with standard antithrombotic agents for VTE prophylaxis. These newer drugs have been compared only to LMWH and show similar effects on most major clinical outcomes, although the strength of evidence varies by drug class and specific drug. In evaluating whether to add these newer agents to the VA formulary and whether to promote a specific thromboprophylaxis strategy, consideration should be given to the evidence of effectiveness and the importance and variability of patient values and preferences, costs, and health care system resources for successfully implementing competing strategies. In the following section, we summarize recommendations from the two major U.S. clinical guideline panels that have addressed this issue.

### Guidelines

Both the American College of Chest Physicians (ACCP) and the American Academy of Orthopaedic Surgeons (AAOS) have recently issued guidelines on thromboprophylaxis in patients undergoing TKR or THR.1,2,24 The ACCP recommends antithrombotic prophylaxis over no prophylaxis for patients undergoing TKR or THR. The AAOS guidelines suggest individual assessment of patients for thromboprophylaxis. For patients at average risk, the guidelines do not include a recommendation for a specific thromboprophylactic strategy, considering the evidence for comparative effectiveness to be inconclusive. In contrast, the ACCP guidelines make recommendations for specific strategies and include the following options: LMWH, fondaparinux, apixaban, dabigatran, rivaroxaban, low-dose unfractionated heparin, adjusted-dose vitamin K antagonists, aspirin, or an intermittent pneumatic compression device. However, in the absence of elevated bleeding risk, LMWH is recommended in preference to other agents. Factors identified as increasing the risk of bleeding include previous major bleeding, severe renal failure, concomitant antiplatelet use, and a history of or difficult-to-control surgical bleeding during the current operative procedure, extensive surgical dissection, and revision surgery.1 For patients with increased bleeding risk, ACCP recommends intermittent pneumatic compression device or no prophylaxis.

In making recommendations, both guideline panels considered benefits and potential harms but had different approaches to considering costs. The AAOS did not conduct cost analyses and instructed guideline members to consider costs only when the impact was likely to be substantial. The ACCP process considered costs when it was plausible that resource use might change the direction or strength of recommendation and when high-quality economic analyses were available; it is not stated whether costs were considered in the recommendations pertaining to major orthopedic surgery. Guideline recommendations regarding choice of thromboprophylaxis are summarized in Table 9. Finally, we note that these guidelines address other clinical management issues, including duration and timing of thromboprophylaxis and use of routine DVT screening, which are not summarized here since they are not directly germane to our key questions.

Table 9 U.S. guideline recommendations related to specific thromboprophylaxis strategies

ACCP 2012^a^ | AAOS 2011^b^
In patients undergoing THR or TKR, we recommend use of one of the following for minimum of 10–14 days rather than no antithrombotic prophylaxis: LMWH, fondaparinux, apixaban, dabigatran, rivaroxaban low-dose unfractionated heparin (LDUH), adjusted-dose VKA, aspirin (all Grade 1B) or an intermittent pneumatic compression device (IPCD) (Grade 1C). | We suggest the use of pharmacologic agents and/or mechanical compressive devices for the prevention of VTE in patients undergoing elective hip or knee arthroplasty, and who are not at elevated risk beyond that of the surgery itself for venous thromboembolism or bleeding. Grade: Moderate
In patients undergoing THR or TKR, irrespective of the concomitant use of an IPCD or length of treatment, we suggest the use of LMWH in preference to the other agents we have recommended as alternatives: fondaparinux, apixaban, dabigatran, rivaroxaban low-dose unfractionated heparin (LDUH) (all Grade 1B), adjusted-dose VKA, aspirin (all Grade 2C). | Current evidence is unclear about which prophylactic strategy is optimal or suboptimal. Therefore, we are unable to recommend for or against specific prophylactics in these patients. Grade: Inconclusive
In patients undergoing major orthopedic surgery, we suggest using dual prophylaxis with an antithrombotic agent and an IPCD during the hospital stay (Grade 2C). | In the absence of reliable evidence, patients who have had a previous VTE should receive pharmacologic prophylaxis and mechanical compressive devices. Grade: Consensus
In patients undergoing major orthopedic surgery and increased risk of bleeding, we suggest using an IPCD or no prophylaxis rather than pharmacologic treatment (Grade 2C). | In the absence of reliable evidence, patients with a known bleeding disorder and/or active liver disease should use mechanical compressive devices for preventing VTE. Grade: Consensus
In patients undergoing major orthopedic surgery and who decline or are uncooperative with injections or an IPCD, we recommend using apixaban or dabigatran (alternatively, rivaroxaban or adjusted-dose VKA if apixaban or dabigatran are unavailable) rather than other forms of prophylaxis (Grade 1B). | In the absence of reliable evidence about how long to employ these prophylactic strategies, it is the opinion of this work group that patients discuss the duration of prophylaxis with their treating physicians. Grade: Consensus

a ACCP evidence grading of evidence was as follows: grade 1 recommendations are strong and indicate that the benefits do or do not outweigh risks, burden, and costs, while grade 2 suggestions imply that individual patient values may lead to different choices. Furthermore, level A indicates consistent results from RCTs or observational studies with very strong association and secure generalization (high), B indicates inconsistent results from RCTs or RCTs with methodological limitations (moderate), C indicates unbiased observational studies (low), and D indicates other observational studies (e.g. case series) (very low).

b AAOS grading was as follows: strong when good-quality evidence, moderate when fair-quality evidence, weak when poor-quality evidence, inconclusive when insufficient or conflicting evidence, or consensus in the absence of reliable evidence.

Abbreviations: IPCD=intermittent pneumatic compression device; LDUH=low-dose unfractionated heparin; LMWH=low molecular weight heparin; THR=total hip replacement; TKR=total knee replacement; VKA=vitamin K antagonist; VTE=venous thromboembolism

## APPLICABILITY

We think these results are likely to apply to Veteran populations, but recommend some caution when applying trial data to standard clinical practice. There were strict exclusion criteria for patients enrolled in these studies, including severe renal or hepatic impairment or high risk of bleeding. Patients enrolled in trials are often more adherent to treatment plans and are monitored more closely than patients in routine clinical care. As a result, treatment effects in standard clinical practice may differ from those observed in clinical trials. Furthermore, the definition of bleeding was not consistent across studies, and it did not always include surgical site bleeding, which can lead to infection, dehiscence, and reoperation. Another limitation is the treatments compared. Newer anticoagulants were compared exclusively with LMWH, an appropriate and widely used comparator, but there were no direct comparisons to other treatment options recommended by guideline panels. Finally, none of these studies included patients from the VA health care system. Compared to patients with private sector insurance, VA patients on average have a greater burden of chronic disease, which would likely increase bleeding risk. If the comparative treatment effects vary by the presence of certain comorbid conditions, these results may not be reproducible in VA settings.

## STRENGTHS AND LIMITATIONS

Our study has a number of strengths, including a protocol-driven review, a comprehensive search, and careful quality assessment. Another strength is the opportunity for meta-synthesis from existing systematic reviews and the opportunity to carefully evaluate reasons for different findings or conclusions across published reviews. Limitations include the lack of head-to-head comparisons of the newer oral anticoagulants, which precludes strong conclusions on their comparative effectiveness. Further, the length of experience with these new anticoagulants is too short to allow identification of longer term adverse events that may only emerge with more widespread use.

## RECOMMENDATIONS FOR FUTURE RESEARCH

We used the framework recommended by Robinson et al.42 to identify gaps in evidence and classify why these gaps exist (Table 10).

Table 10 Evidence gaps and future research

Evidence Gap | Reason | Type of Studies to Consider
Absence of direct comparisons between newer anticoagulant drugs | Insufficient information | Multicenter RCTs High-quality network meta-analyses Observational comparative effectiveness studies
Absence of direct comparisons between newer anticoagulants and agents other than LMWH | Insufficient information | Multicenter RCTs Observational comparative effectiveness studies
Absence of comparisons between combined treatment with newer anticoagulants and mechanical thromboprophylaxis to pharmacological thromboprophylaxis alone | Insufficient information | Multicenter RCTs Observational comparative effectiveness studies
Adverse effects with long-term use and in usual clinical practice | Insufficient information | Observational studies

Abbreviations: LMWH=low molecular weight heparin; RCT=randomized controlled trial

This approach considers PICOTS (population, intervention, comparator, outcomes, timing, and setting) to identify gaps and classifies them as due to: (1) insufficient or imprecise information, (2) biased information, (3) inconsistency or unknown consistency, and (4) not the right information. VA and other health care systems should consider their clinical and policy needs when deciding whether to invest in research to address gaps in evidence. Specific research questions can be evaluated quantitatively, using value-of-information analysis, which uses Bayesian methods to estimate the potential benefits of gathering further information through research.43

## CONCLUSION

For THR or TKR, the 35-day rate of symptomatic VTE without thromboprophylaxis is estimated to be 4.3 percent. Pharmacological thromboprophylaxis decreases VTE by approximately 50 percent but with the tradeoff of increased bleeding. Newer oral anticoagulants have a more convenient route of administration compared with LMWH, and unlike adjusted dose warfarin, they do not require regular laboratory monitoring. Compared with LMWH, FXa inhibitors are associated with a reduced risk of symptomatic DVT, but mortality and nonfatal PE are not significantly different, and the risk of major bleeding episodes is increased.

There are no available studies on head-to-head comparisons of these novel anticoagulants. Longer clinical experience and direct drug-drug comparisons are needed to better assess the risk-to-benefit ratio of newer oral anticoagulants for surgical thromboprophylaxis. Based on current evidence, newer anticoagulants—particularly FXa inhibitors—are a reasonable option for thromboprophylaxis in patients undergoing total hip replacement or total knee replacement.