# REFERENCES

1 Falck-Ytter Y, Francis CW, Johanson NA, et al. Prevention of VTE in orthopedic surgery patients: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. 2012;141(2 Suppl):e278S-325S. [pmid: 22315265].
2 Mont MA, Jacobs JJ, Boggio LN, et al. Preventing venous thromboembolic disease in patients undergoing elective hip and knee arthroplasty. J Am Acad Orthop Surg. 2011;19(12):768-76. [pmid: 22134209].
3 Hill J, Treasure T. Reducing the risk of venous thromboembolism (deep vein thrombosis and pulmonary embolism) in inpatients having surgery: summary of NICE guidance. BMJ. 2007;334(7602):1053-4. [pmid: 17510154].
4 Friedman RJ, Gallus A, Gil-Garay E, et al. Practice patterns in the use of venous thromboembolism prophylaxis after total joint arthroplasty—insights from the Multinational Global Orthopaedic Registry (GLORY). Am J Orthop (Belle Mead NJ). 2010;39(9 Suppl):14-21. [pmid: 21290027].
5 Binns M, Pho R. Femoral vein occlusion during hip arthroplasty. Clin Orthop Relat Res. 1990;(255):168-72. [pmid: 2189628].
6 Clark C, Cotton LT. Blood-flow in deep veins of leg. Recording technique and evaluation of methods to increase flow during operation. Br J Surg. 1968;55(3):211-4. [pmid: 5637094].
7 Planes A, Vochelle N, Fagola M. Total hip replacement and deep vein thrombosis. A venographic and necropsy study. J Bone Joint Surg Br. 1990;72(1):9-13. [pmid: 2298803].
8 Sharrock NE, Go G, Harpel PC, et al. The John Charnley Award. Thrombogenesis during total hip arthroplasty. Clin Orthop Relat Res. 1995;(319):16-27. [pmid: 7554626].
9 Sobieraj DM, Coleman CI, Tongbram V, et al. Venous Thromboembolism in Orthopedic Surgery, Comparative Effectiveness Review No. 49. (Prepared by the University of Connecticut/Hartford Hospital Evidence-based Practice Center under Contract No. 290-2007-10067-I). AHRQ Publication No 12-EHC020-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm. Accessed November 7, 2012.
10 Lieberman JR, Hsu WK. Prevention of venous thromboembolic disease after total hip and knee arthroplasty. J Bone Joint Surg Am. 2005;87(9):2097-112. [pmid: 16140827].
11 Molnar RB, Jenkin DE, Millar MJ, et al. The Australian arthroplasty thromboprophylaxis survey. J Arthroplasty. 2012;27(2):173-9. [pmid: 21752576].
12 Ettema HB, Mulder MC, Nurmohamed MT, et al. Dutch orthopedic thromboprophylaxis: a 5-year follow-up survey. Acta Orthop. 2009;80(1):109-12. [pmid: 19234891].
13 Hirsh J, Levine MN. Low molecular weight heparin: laboratory properties and clinical evaluation. A review. Eur J Surg Suppl. 1994;(571):9-22. [pmid: 7519092].
14 Weitz JI. Low-molecular-weight heparins. N Engl J Med. 1997;337(10):688-98. [pmid: 9278467].
15 Turpie AG. Pentasaccharide Org31540/SR90107A clinical trials update: lessons for practice. Am Heart J. 2001;142(2 Suppl):S9-15. [pmid: 11479485].
16 Fareed J, Thethi I, Hoppensteadt D. Old versus new oral anticoagulants: focus on pharmacology. Annu Rev Pharmacol Toxicol. 2012;52:79-99. [pmid: 21819239].
17 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. J Clin Epidemiol. 2009;62(10):1006-12. [pmid: 19631508].
18 Montori VM, Wilczynski NL, Morgan D, et al. Optimal search strategies for retrieving systematic reviews from MEDLINE: analytical survey. BMJ. 2005;330(7482):68. [pmid: 15619601].
19 Shojania KG, Bero LA. Taking advantage of the explosion of systematic reviews: an efficient MEDLINE search strategy. Eff Clin Pract. 2001;4(4):157-62. [pmid: 11525102].
20 Neumann I, Rada G, Claro JC, et al. Oral direct factor Xa inhibitors versus lowmolecular-weight heparin to prevent venous thromboembolism in patients undergoing total hip or knee replacement a systematic review and meta-analysis. Ann Intern Med. 2012;156(10):710-719. [pmid: 22412038].
21 Loke YK, Kwok CS. Dabigatran and rivaroxaban for prevention of venous thromboembolism--systematic review and adjusted indirect comparison. J Clin Pharm Ther. 2011;36(1):111-24. [pmid: 21198726].
22 Ringerike T, Hamidi V, Hagen G, et al. Thromboprophylactic treatment with rivaroxaban or dabigatran compared with enoxaparin or dalteparin in patients undergoing elective hip- or knee replacement surgery. Report from NOKC nr 13 - 2011. Health Technology Assessment (HTA). 2011.
23 Gómez-Outes A, Terleira-Fernández AI, Suárez-Gea ML, et al. Dabigatran, rivaroxaban, or apixaban versus enoxaparin for thromboprophylaxis after total hip or knee replacement: systematic review, meta-analysis, and indirect treatment comparisons. BMJ. 2012;344.
24 Jacobs JJ, Mont MA, Bozic KJ, et al. American Academy of Orthopaedic Surgeons clinical practice guideline on: preventing venous thromboembolic disease in patients undergoing elective hip and knee arthroplasty. J Bone Joint Surg Am. 2012;94(8):746-7. [pmid: 22517391].
25 Marinopoulos SS, Dorman T, Ratanawongsa N, et al. Effectiveness of continuing medical education. Evid Rep Technol Assess (Full Rep). 2007;(149):1-69.
26 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-900. [pmid: 10584742].
27 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
28 Mills EJ, Ioannidis JP, Thorlund K, et al. How to use an article reporting a multiple treatment comparison meta-analysis. JAMA. 2012;308(12):1246-53. [pmid: 23011714].
29 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. Available at: www.effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&mp=1&productID=318. Accessed August 1, 2012.
30 Guyatt GH, Oxman AD, Kunz R, et al. GRADE guidelines 6. Rating the quality of evidence--imprecision. J Clin Epidemiol. 2011;64(12):1283-93. [pmid: 21839614].
31 Schunemann HJ, Oxman AD, Brozek J, et al. Grading quality of evidence and strength of recommendations for diagnostic tests and strategies. BMJ. 2008;336(7653):1106-10. [pmid: 18483053].
32 Cao YB, Zhang JD, Shen H, et al. Rivaroxaban versus enoxaparin for thromboprophylaxis after total hip or knee arthroplasty: a meta-analysis of randomized controlled trials. Eur J Clin Pharmacol. 2010;66(11):1099-108. [pmid: 20812009].
33 Huang J, Cao Y, Liao C, et al. Apixaban versus enoxaparin in patients with total knee arthroplasty. A meta-analysis of randomised trials. Thromb Haemost. 2011;105(2):245-53. [pmid: 20941455].
34 Turun S, Banghua L, Yuan Y, et al. A systematic review of rivaroxaban versus enoxaparin in the prevention of venous thromboembolism after hip or knee replacement. Thromb Res. 2011;127(6):525-34. [pmid: 21397931].
35 Alves C, Batel-Marques F, Macedo AF. Apixaban and Rivaroxaban Safety After Hip and Knee Arthroplasty: A Meta-Analysis. J Cardiovasc Pharmacol Ther. 2011.
36 Eriksson BI, Borris LC, Friedman RJ, et al. Rivaroxaban versus enoxaparin for thromboprophylaxis after hip arthroplasty. N Engl J Med. 2008;358(26):2765-75. [pmid: 18579811].
37 Kakkar AK, Brenner B, Dahl OE, et al. Extended duration rivaroxaban versus short-term enoxaparin for the prevention of venous thromboembolism after total hip arthroplasty: a double-blind, randomised controlled trial. Lancet. 2008;372(9632):31-9. [pmid: 18582928].
38 Lassen MR, Ageno W, Borris LC, et al. Rivaroxaban versus enoxaparin for thromboprophylaxis after total knee arthroplasty. N Engl J Med. 2008;358(26):2776-86. [pmid: 18579812].
39 Turpie AG, Lassen MR, Davidson BL, et al. Rivaroxaban versus enoxaparin for thromboprophylaxis after total knee arthroplasty (RECORD4): a randomised trial. Lancet. 2009;373(9676):1673-80. [pmid: 19411100].
40 Eriksson BI, Dahl OE, Buller HR, et al. A new oral direct thrombin inhibitor, dabigatran etexilate, compared with enoxaparin for prevention of thromboembolic events following total hip or knee replacement: the BISTRO II randomized trial. J Thromb Haemost. 2005;3(1):103-11. [pmid: 15634273].
41 Bucher HC, Guyatt GH, Griffith LE, et al. The results of direct and indirect treatment comparisons in meta-analysis of randomized controlled trials. J Clin Epidemiol. 1997;50(6):683-91. [pmid: 9250266].
42 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for Determining Research Gaps During Systematic Reviews, Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I). AHRQ Publication No 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm. Accessed May 22, 2012.
43 Myers E, McBroom AJ, Shen L, et al. Value-of-Information Analysis for Patient-Centered Outcomes Research Prioritization. Report prepared by the Duke Evidence-based Practice Center. Patient-Centered Outcomes Research Institute. March. 2012.